# Rehabilitación después de un ataque cerebral

## ¿Qué es un ataque cerebral?

Un ataque o derrame cerebral es un tipo de lesión al cerebro. Los síntomas dependerán de la parte del cerebro que se ha afectado. Frecuentemente las personas que sobreviven un ataque cerebral padecen de debilidad en un lado del cuerpo, o tienen problemas para moverse, hablar o pensar.

La mayoría de los ataques son isquémicos y son causados por una reducción en el flujo de la sangre al cerebro. Esto sucede cuando los vasos sanguíneos están bloqueados por un coágulo, o son demasiado estrechos para que pase la sangre. Las células del cerebro en esa área en particular mueren debido a la falta de oxígeno. Otro tipo de ataque, llamado hemorrágico o derrame, sucede cuando un vaso sanguíneo se rompe y derrama sangre en el cerebro, causando así la lesión.

Los ataques son más comunes entre las personas de edad avanzada. Casi 3 de cada 4 víctimas son mayores de 65 años de edad. Sin embargo, cualquier persona puede tener un ataque cerebral.

La persona también puede tener un ataque transitorio isquémico que presenta los mismos síntomas que el ataque cerebral, pero éstos sólo duran unas cuantas horas o un día; y no causan daño cerebral permanente. No son ataques en sí, pero son un síntoma de advertencia muy importante. La persona que tiene estos ataques necesita tratamiento para prevenir un ataque cerebral en el futuro.

El ataque cerebral puede atemorizar al paciente y a sus familiares, pero es importante que recuerde que los pacientes que sobreviven estos ataques tienen cierto grado de recuperación que sucede naturalmente, y que se pueden recuperar aún más gracias a un programa de rehabilitación.

## El propósito de esta publicación

Esta publicación trata sobre la rehabilitación después de un ataque cerebral. Su propósito es que el paciente tenga la mejor recuperación posible y que obtenga los mayores beneficios del programa de rehabilitación.

Encontrará que nos referimos al paciente como "persona" o "superviviente" porque las personas que han padecido un ataque cerebral son "pacientes" sólo durante el período inmediato al ataque y durante el programa de rehabilitación. Después de esto, simplemente son "personas" que en el pasado sufrieron un ataque cerebral. La expresión "familiar" describe a aquéllos cercanos al superviviente, ya sean familiares o amigos. Finalmente, usamos doctor o enfermera para describir a éstos o cualquier otro profesional a cargo del cuidado del paciente.

La rehabilitación es más eficaz cuando el paciente y la familia cooperan como un equipo. Por esta razón, invitamos a ambos a que lean esta publicación en su totalidad.

## La recuperación después de un ataque cerebral

El proceso de recuperación tiene diferentes aspectos que incluyen el tratamiento, recuperación espontánea, rehabilitación, y el regresar a la vida cotidiana (normal). Cada persona tiene diferentes necesidades de rehabilitación y, por lo tanto, progresa de diferente manera.

Tratamiento. Este se inicia en el hospital durante el "cuidado intensivo" para tratar de asegurar que el paciente sobreviva, la prevención de otro ataque, y cuidar de cualesquiera otros problemas médicos.

Recuperación espontánea. Esta sucede naturalmente en la mayoría de los pacientes. Pronto después del ataque, la persona recupera algunas capacidades que había perdido con el ataque. Este proceso es más rápido durante las primeras semanas, pero a veces puede prolongarse por largo tiempo.

Rehabilitación (pasos específicos para ayudar a la recuperación). Esta es otra parte del tratamiento. Ayuda a la persona a hacerse más independiente, manteniendo capacidades que ya tenía y tratando de recuperar aquéllas que perdió. Normalmente se inicia cuando el paciente aún está bajo cuidado intensivo y, para muchos continúa después, ya sea como un programa formal o como servicios individuales. Muchas de las decisiones en cuanto a la rehabilitación se hacen antes de dar al paciente de alta del cuidado intensivo y las toman el paciente mismo, los familiares y el personal médico del hospital.

La vida cotidiana (diaria). Esta es la última etapa de recuperación y es cuando el paciente regresa a su comunidad y vida diarias después del cuidado intensivo o de rehabilitación. Esta etapa puede prolongarse por el resto de la vida de la persona. Tanto ésta como su familia aprenden a vivir con los efectos del ataque. Esto puede incluir nuevas formas de compensar con otras partes del cuerpo por aquéllas que han sufrido daño o limitaciones. Por ejemplo, con el uso del velcro en vez de cintas para amarrar los zapatos, o aprender a escribir con la mano opuesta.

## Los efectos de los ataques cerebrales

### Efectos en el cuerpo, la mente, y las emociones

Cada ataque es diferente, dependiendo de la parte del cerebro que afecta, la extensión de la lesión, y el estado general de salud de la persona. Algunos de los efectos son:

- Debilidad (hemiparálisis) o parálisis (hemiplegia) en un lado del cuerpo. Esta puede afectar un lado completo del cuerpo, o sólo el brazo o la pierna. Sucede en el lado opuesto al hemisferio del cerebro que sufrió el ataque. Por ejemplo, si el hemisferio lesionado es el izquierdo, la debilidad o parálisis se presentará en el lado derecho del cuerpo.
- Problemas de equilibrio o coordinación. Esto puede hacer difícil que la persona se siente, pare, o camine; a pesar que los músculos tienen suficiente fuerza.
- Problemas de lenguaje (afasia y disartria). Cuando la persona tiene afasia, puede tener problemas para entender el lenguaje hablado o escrito; o entiende pero no puede recordar las palabras para hablar o escribir. Cuando la persona tiene disartria, sabe las palabras correctas, pero no las puede enunciar claramente.
- No percibir o ignorar un lado del cuerpo (negligencia corporal). Frecuentemente, la persona no voltea a ver hacia el lado débil, o ni siquiera come alimentos en ése lado de la boca.
- Dolor, adormecimiento, o sensaciones no familiares. Estas pueden impedir que la persona se relaje y se sienta cómoda.
- Problemas de memoria, razonamiento, atención, o aprendizaje (problemas cognitivos). La persona puede tener problemas con varias o muchas capacidades mentales. Por ejemplo, puede tener problemas al tratar de seguir instrucciones, puede confundirse si mueven algo en la habitación, o puede ser incapaz de mantener claras la fecha o la hora.
- No tener consciencia de los efectos del ataque. La persona puede perder su capacidad de buen juicio y por lo tanto tratar de hacer cosas que son peligrosas debido a los efectos del ataque.
- Problemas para tragar (disfagia). Puede complicar la nutrición adecuada de la persona. Es importante tener cuidado para evitar que la persona no vaya a aspirar un trozo de comida mientras está tratando de tragar.
- Problemas de control de orina o fecal. Se puede ayudar a la persona con el uso de orinales, cómodos, y otros utensilios de este tipo.
- Que la persona se cansa rápidamente. Cuando la persona se cansa rápidamente, limita su participación y desempeño en el programa de rehabilitación.
- Explosiones emocionales súbitas, como risa, llanto o furia. Estas emociones pueden indicar que la persona necesita ayuda, comprensión y apoyo en su proceso de adaptación a los efectos del ataque.
- Depresión. Es muy común entre las personas que han sufrido un ataque cerebral y puede presentarse poco después o varias semanas después del ataque. Frecuentemente los familiares son los primeros en notarla.

#### La depresión después de un ataque cerebral

Es normal que una persona que ha sufrido un ataque cerebral se sienta triste. Sin embargo, algunas personas pueden padecer un desorden depresivo mayor; que se debe diagnosticar y tratar lo antes posible. Una persona que padece un desorden depresivo mayor tiene varios síntomas, todos los días, durante todo el día, por lo menos por dos semanas. Estos síntomas siempre incluyen por lo menos uno de los siguientes:

- Sentirse triste y melancólico.
- Perder interés en las cosas que antes se disfrutaban.

La persona también puede presentar otros síntomas físicos o psicológicos que incluyen:

- Sentirse agitado o lento, inquieto o que no puede permanecer tranquilo.
- Sentirse culpable o con muy baja autoestima.
- Aumento o reducción del apetito y el peso.
- Problemas para concentrarse, pensar, recordar o tomar decisiones.
- Problemas para dormir, o dormir demasiado.
- Perder la energía o sentirse cansado todo el tiempo.
- Dolores de cabeza.
- Otros dolores y molestias.
- Problemas de la digestión.
- Problemas en la función sexual.
- Sentirse pesimista y sin esperanza.
- Sentirse ansioso y preocupado.
- Pensamientos de la muerte o el suicidio.

Si la persona tiene síntomas de depresión, especialmente pensamientos de la muerte o el suicidio, necesita ayuda profesional inmediata. Una vez que se ha tratado la depresión, estos sentimientos desaparecerán. La depresión se puede tratar con medicamentos, psicoterapia, o ambos. Si no se da tratamiento, puede causar sufrimiento innecesario y puede hacer más difícil la recuperación del ataque cerebral.

#### Incapacitaciones después de un ataque cerebral

Una "incapacitación" es que se haga difícil el realizar alguna tarea o actividad que es parte normal de la vida diaria. Las personas que han sufrido ataques cerebrales pueden encontrar dificultad en muchas actividades antes sencillas tales como caminar, hablar o realizar sus "actividades diarias". Estas incluyen tareas básicas como bañarse, vestirse, alimentarse y usar el inodoro (baño). También puede haber dificultad al realizar otras tareas más complejas, conocidas como "actividades instrumentales", tales como mantener el hogar, usar el teléfono, guiar un auto, y escribir cheques.

Algunas incapacitaciones se hacen evidentes inmediatamente después del ataque y otras se notan hasta que la persona ha regresado a casa y trata de realizar alguna tarea por primera vez después del ataque.

## Lo que sucede durante el cuidado intensivo

Las metas principales del cuidado intensivo son las siguientes:

- Asegurarse que los síntomas son el resultado de un ataque cerebral y no alguna otra condición médica.
- Determinar el tipo y ubicación del ataque y su grado de gravedad.
- Prevenir y tratar complicaciones tales como incontinencia urinaria o fecal y úlceras por contacto.
- Prevenir otro ataque cerebral.
- Tan pronto como sea medicamente posible, animar al paciente a que se mueva y realice tareas de cuidado personal tales como comer y levantarse de la cama. Este es el primer paso de la rehabilitación.

Antes que termine el cuidado intensivo, el paciente, su familia y el personal deciden cuál será el siguiente paso. Para muchos pacientes, el siguiente paso es continuar con la rehabilitación.

La estadía en el hospital puede crear confusión para el paciente o sus familiares. El personal médico está a su servicio. Puede consultar con ellos sobre sus preguntas y hablar sobre todos los temas que le preocupen.

## La prevención de otro ataque

Las personas que ya han padecido un ataque cerebral tienen mayor riesgo de padecer otro, especialmente durante el primer año. El riesgo aumenta con: La edad avanzada, alta presión sanguínea (hipertensión), colesterol alto, diabetes, obesidad, haber sufrido un ataque transitorio isquémico, enfermedades cardíacas, fumar, beber mucho alcohol, y drogadicción. Algunos de estos factores de riesgo no se pueden controlar, como la edad; pero otros se pueden reducir con el uso de medicamentos y cambios en el estilo de vida.

Los pacientes y sus familias deben pedir recomendaciones del médico o la enfermera en cuanto a la prevención de otro ataque y cooperar con ellos para hacer los cambios necesarios en el estilo de vida del paciente. También deben aprender sobre los síntomas indicativos de un ataque transitorio isquémico (debilidad de un lado del cuerpo y dificultad al hablar), y ver a un médico de inmediato si estos síntomas se presentan.

## Decisiones en cuanto a la rehabilitación

Algunas personas no necesitan rehabilitación porque el ataque fue leve o se han recuperado completamente. Otros pueden estar demasiado incapacitados para participar. Sin embargo, muchos pacientes pueden beneficiarse de la rehabilitación. El médico y la enfermera ayudarán a la familia y al paciente a encontrar el mejor tipo de rehabilitación en cada caso.

### Tipos de programas de rehabilitación

Existen varios tipos de programas de rehabilitación:

- Programas de hospital. Se proporcionan en hospitales de rehabilitación o en unidades en hospitales de cuidado intensivo que cuentan con servicios completos de rehabilitación. El paciente permanece en el hospital durante el programa y está bajo el cuidado de profesionales capacitados quienes le dan las terapias. Los programas de hospital normalmente son más intensivos que otros programas y requieren más esfuerzo por parte del paciente.
- Programas de asilo de ancianos. Al igual que los anteriores, el paciente permanece internado durante el programa de rehabilitación. Los programas en los asilos de ancianos varían, así es que es importante obtener información acerca de cada uno; ya que algunos proporcionan servicios de rehabilitación completos, y otros proporcionan servicios limitados.
- Programas de consulta externa. Estos permiten que un paciente que vive en casa reciba todos sus servicios de rehabilitación acudiendo a uno de los siguientes: Departamento de consulta externa de un hospital, una institución especializada en rehabilitación, o programas de cuidado diurno en un hospital.
- Programas en casa. El paciente permanece en casa y recibe servicios de profesionales ambulantes (enfermeras/terapistas). Una ventaja de estos programas, es que el paciente aprende las capacidades que necesita para vivir, justo en el lugar en donde más las tendrá que usar.

### Servicios de rehabilitación individuales

Muchos pacientes no necesitan servicios de rehabilitación completos, sino que requieren servicios individuales tales como terapia física o de lenguaje. Estos servicios están disponibles en los departamentos de consulta externa en hospitales y en programas de rehabilitación en el hogar.

### Pagar por el costo del programa de rehabilitación

El Medicare y muchas compañías de seguro de salud ayudan a pagar los costos de la rehabilitación. Medicare es el programa federal de seguro de salud para las personas mayores de 65 años de edad y para otros individuos con ciertas incapacitaciones. Consta de dos partes: el seguro de hospital (conocido como Parte A) y seguro médico suplementario (conocido como Parte B). La Parte A ayuda a pagar el cuidado en casa, en "hospice" (donde se proporcionan servicios a pacientes en etapas de enfermedad terminal), cuidado hospitalario, y cuidado de asilo de ancianos. La Parte B ayuda a pagar los servicios de los doctores, los servicios de cuidado externo, equipo médico a largo plazo, y otros servicios y equipos médicos que no se cubren en la Parte A. Las oficinas de la "Social Security Administration" en todo el país pueden darle copias de solicitudes para el Medicare y proporcionarle información sobre el programa.

En algunos casos el Medicare ayudará a pagar por los servicios de consulta externa de una institución de rehabilitación que participe en Medicare. Los servicios que cubre incluyen: Terapias física, de lenguaje, ocupacional y respiratoria; consejería; y otros servicios relacionados. Para obtener estos beneficios, un médico debe referir al paciente y certificar que requiere de servicios especializados de rehabilitación.

El Medicaid es un programa federal regido por cada estado del país. Cada estado decide cuáles personas pueden recibir la totalidad de servicios de salud disponibles. Medicaid proporciona cobertura para ciertas personas de ingresos bajos que no pueden pagar por servicios médicos, incluyendo a ciertas personas que reciben servicios por ser mayores, ciegas, incapacitadas, o ciertos individuos en familias con niños dependientes.

Ambos programas tienen ciertas restricciones y limitaciones en la cobertura y pueden decidir suspenderla en cuanto el paciente deje de mostrar progreso. Por esta razón, es importante que los pacientes y sus familias se informen claramente en cuanto a su seguro de salud y los servicios que cubrirá. Los hospitales cuentan con departamentos de servicios sociales que pueden responder a sus preguntas en cuanto a seguros de salud, y le pueden ayudar a planificar sus deudas y pagos.

## La selección de un programa de rehabilitación

El médico y otros miembros del personal del hospital le darán información y recomendaciones en cuanto a los programas de rehabilitación; pero el paciente y su familia tienen que tomar la decisión final. Los miembros del equipo de cuidado del hospital conocen las incapacitaciones y condición médica del paciente y deben conocer los programas de rehabilitación de la comunidad y pueden responder a sus preguntas sobre estos programas. El paciente y su familia pueden tener ciertas preferencias en cuanto a si el paciente debe permanecer en casa o en la institución de rehabilitación y tienen sus razones para preferir un programa u otro. Sus preocupaciones son importantes y las deben hablar con el personal del hospital.

### Lo que debe considerar cuando seleccione un programa de rehabilitación

- ¿Proporciona todos los servicios que necesita el paciente?
- ¿Coincide con las capacidades del paciente, o le pide demasiado, o demasiado poco?
- ¿Qué tipo de prestigio tiene la calidad de cuidado del programa dentro de la comunidad?
- ¿Está certificado y cuenta con personal con credenciales apropiadas?
- ¿Está ubicado en un lugar a donde la familia puede ir a visitar sin problemas?
- ¿Involucra al paciente y los familiares en el proceso de decisiones en cuanto a la rehabilitación?
- ¿Permite que los familiares participen en las sesiones de rehabilitación y que practiquen las técnicas con el paciente?
- ¿Qué tanto cubre el seguro o Medicare de los costos de la rehabilitación?
- Si es un programa de consulta externa, ¿hay alguien en casa que pueda proporcionar el cuidado diario?
- Si es un programa de consulta externa, ¿existe transportación disponible?

Es probable que una persona inicie su programa de rehabilitación en una institución y que luego transfiera a otra. Por ejemplo, un paciente que se cansa fácilmente puede empezar el programa más lentamente en un asilo y luego, conforme se sienta más fuerte, puede transferir a un programa más intensivo.

### Casos en los que no se recomienda la rehabilitación

Algunas familias y pacientes se sienten decepcionados si el médico no recomienda un programa de rehabilitación. Sin embargo, esto puede ser debido a que la persona puede estar inconsciente o demasiado incapacitada para beneficiarse. Por ejemplo, una persona puede no estar capacitada para aprender y la mejor ayuda que se le puede dar es cuidado rutinario en casa o en un asilo. Un paciente que en un principio está demasiado débil para un programa de rehabilitación, puede beneficiarse de un período gradual de recuperación en casa o en un asilo y considerar la rehabilitación más tarde. Es importante que recuerde que:

- El personal del hospital tiene la responsabilidad de ayudarle a planear el mejor cuidado para el paciente después que se le dé de alta del cuidado intensivo. También puede proporcionar o hacer arreglos para servicios sociales necesarios y educación sobre la condición para la familia.
- Esta no es la única oportunidad para participar en un programa de rehabilitación. Existen pacientes que están demasiado incapacitados en un principio quienes se reponen lo suficiente para iniciar rehabilitación más tarde.

## Lo que sucede durante la rehabilitación

Durante el programa de rehabilitación en un hospital o asilo, el paciente pasa varias horas al día en actividades tales como la terapia física, ocupacional, del lenguaje, recreacional, actividades de grupo y educación para el paciente y la familia. Es importante mantener capacidades (tales como caminar y hablar) que el paciente tenía antes del ataque cerebral. Parte del tiempo se usa en enseñar al paciente nuevas formas de hacer ciertas cosas (por ejemplo, usar sólo una mano para realizar tareas que antes hacía con dos).

### Establecer metas de rehabilitación

Las metas de rehabilitación dependen de los efectos del ataque cerebral, lo que el paciente podía hacer antes del ataque, y los deseos del paciente. Cooperando, el paciente, su familia, y el grupo de rehabilitación pueden establecer metas para el programa. En ocasiones, la persona tiene que repetir ciertos pasos de la terapia para lograr alguna meta.

Es importante que las metas del programa sean realísticas. Para ayudar a lograr estas metas, es necesario que el paciente y su familia hablen con el personal del programa sobre las cosas que él/ella quiere poder hacer. Esto es debido a que si las metas son demasiado altas, el paciente no las podrá alcanzar. Si son demasiado bajas, el paciente no recibirá todos los beneficios del programa o, si las metas no le interesan, no hará el mismo esfuerzo para lograrlas.

#### Metas de rehabilitación

- Poder caminar, con un bastón o una andadera (estante doble con o sin ruedas que ayuda al equilibrio y a caminar), es una meta realística para la mayoría de las personas que han sufrido un ataque cerebral.
- Cuidar de sí mismos con la ayuda de cierto equipo especial es una meta realística para la mayoría.
- Guiar un auto es una meta realística para algunos.
- Trabajar puede ser una meta realística para las personas que trabajaban antes del ataque. Para algunos, realizar el trabajo que tenían antes ya no es posible, pero un nuevo trabajo o un trabajo como voluntario es posible.

Lograr las metas del programa no quiere decir que se ha terminado la recuperación. Sólo quiere decir que el paciente y su familia están listos para continuar con la recuperación sin asistencia.

### Especialistas de rehabilitación

Dado que cada ataque cerebral es diferente, el tratamiento para cada individuo será diferente y existen diferentes especialistas capacitados para proporcionar los servicios de rehabilitación. La persona puede trabajar con cualquiera de los siguientes:

- Médico. Todos los pacientes en rehabilitación después de un ataque cerebral están bajo el cuidado de un médico. Existen varios tipos de médicos de rehabilitación que cumplen esta tarea, incluyendo: Médicos de familia (cabecera) o internistas, geriatras (especializados en personas de edad avanzada), neurólogos (especialistas en el cerebro y el sistema nervioso), y médicos especializados en medicina física y rehabilitación.
- Enfermera de rehabilitación. Se especializa en el cuidado de personas con incapacitaciones y provee cuidado directo, educación para el paciente y su familia y asiste al médico para coordinar todo el cuidado.
- Especialista de terapia física. Evalúa y trata problemas con la capacidad de movimiento, el equilibrio y la coordinación física. Proporciona capacitación y ejercicios para mejorar el caminar, acostarse, sentarse, y levantarse de camas o sillas, y moverse sin perder el equilibrio. También capacita a los familiares en ayudar al paciente con los ejercicios y, si es necesario, a ayudarle a moverse y caminar.
- Especialista en terapia ocupacional. Da ejercicios y práctica para que los pacientes puedan hacer las cosas que podían hacer antes del ataque, como comer, bañarse, vestirse, escribir, o cocinar. Ciertas tareas ya no se pueden realizar de una manera, así es que el terapista se encarga de enseñar al paciente nuevas técnicas para realizarlas.
- Patólogo del habla y del lenguaje. Ayuda al paciente a recuperar sus capacidades de lenguaje y a aprender nuevas formas de comunicarse. También es importante enseñarle a la familia a mejorar la comunicación con el paciente. Trabaja con los pacientes que tienen problemas para tragar (disfagia).
- Trabajador social. Ayuda a los pacientes y sus familias a tomar decisiones en cuanto a la rehabilitación y a tener un plan para regresar a casa o a un nuevo lugar en donde vivir. Responde a las dudas en cuanto a seguro de salud y pagos por los costos; y ayuda a hacer arreglos para otros servicios disponibles. También puede hacer arreglos para que la familia y el paciente reciban servicios de consejería para ayudar con los posibles problemas emocionales.
- Psicólogo. Trata de ayudar con la salud mental del paciente a través de entrevistas y pláticas para identificar y entender los problemas. Puede proporcionar tratamiento para problemas de memoria o de capacidad de razonamiento y proveer apoyo para otros profesionales que trabajan con pacientes con este tipo de problemas.
- Especialista en terapia recreativa. Ayuda a los pacientes a volver a realizar las actividades recreativas que disfrutaban antes del ataque cerebral; tales como jugar cartas, cuidar el jardín, boliches, o actividades de la comunidad. La terapia recreativa ayuda en el proceso de rehabilitación y anima al paciente a practicar ciertas capacidades.
- Otros profesionales. Existen otros profesionales que pueden colaborar en el tratamiento de un paciente. Por ejemplo, un ortoterapista puede hacer aparatos especiales para dar apoyo a los pies y los tobillos débiles. Un urólogo puede tratar problemas de la vejiga; y otros especialistas pueden ayudar con los problemas emocionales y médicos. Los especialistas en dietética se aseguran que el paciente tenga una alimentación adecuada durante su rehabilitación y educan a la familia en cuanto a la nutrición del paciente después del programa. Los especialistas en terapia vocacional pueden ayudar al paciente a regresar al trabajo o a la escuela.

Para que el proceso de rehabilitación sea exitoso, los profesionales, la familia y el paciente deben trabajar y cooperar.

### El grupo de rehabilitación

En muchos programas, se organiza un grupo especial de rehabilitación para cada paciente. Este grupo consta de paciente, familia y los profesionales de rehabilitación. El grupo se reúne regularmente para hablar sobre el progreso del paciente durante el tratamiento. Normalmente, estos grupos ayudan a que todos los componentes trabajen en conjunto para lograr las metas.

## Obtener los mayores beneficios de la rehabilitación

### Lo que puede hacer el paciente

Si usted es la persona que ha tenido el ataque cerebral, recuerde que usted es quien más importa en su propio tratamiento. Es usted quien tiene derecho a tomar las decisiones más importantes, aunque a veces esto puede ser difícil. A veces probablemente preferiría dejar que el personal de rehabilitación tomara las decisiones por usted. Es importante, sin embargo, que si tiene dificultad para hablar tome el tiempo necesario para pensar sobre sus decisiones. Tiene que tratar de impedir que otros se adelanten a tomar decisiones por usted.

- Asegúrese de decirle a otros que usted quiere tomar sus propias decisiones en cuanto al cuidado.
- Discuta sus preguntas y preocupaciones con el personal del programa.
- Exprese sus deseos y opiniones en cuanto a las decisiones que le afectan.
- Haga que le escuchen cuando sienta que "le hablan como si fuera un niño"; o si la gente empieza a hablar sobre usted como si no existiera.
- Recuerde que tiene todo el derecho de ver su archivo médico.

Para desempeñar un papel en su cuidado médico, es necesario que se mantenga informado sobre el tratamiento y su propio progreso. Puede que le ayude mantener notas sobre el tratamiento y su progreso y escribir cualquier pregunta que tenga.

Expresar sus necesidades puede ser difícil si tiene problemas del habla. El patólogo del lenguaje puede ayudarle a comunicarse con los demás miembros del grupo de cuidado; o los miembros de su familia también le pueden ayudar a comunicar sus ideas y necesidades.

La mayoría de los pacientes encuentran que el trabajo de rehabilitación es difícil ya que tienen que mantener capacidades al mismo tiempo que tratan de volver a desarrollar capacidades perdidas. Es normal que a veces se sienta desalentado porque es tan difícil hacer cosas que eran tan sencillas antes del ataque. Trate de notar su progreso y disfrute cada logro.

### Maneras en que la familia puede ayudar

Si es familiar de una persona que tuvo un ataque cerebral, éstas son algunas de las cosas que puede hacer para ayudarle:

- Apoye los esfuerzos del paciente para participar en las decisiones del programa de rehabilitación.
- Visite y hable con el paciente. Traten de relajarse juntos ya sea jugando cartas, viendo la televisión, escuchando la radio, o jugando un juego de mesa.
- Si el paciente tiene problemas de comunicación (afasia), hable con el patólogo del lenguaje para que le diga cómo puede ayudar más tarde.
- Participe en los programas de educación para el paciente y su familia y trate de aprender todo lo posible para ayudar.
- Pida que le dejen acudir a las sesiones de rehabilitación. Esta es una buena manera de aprender cómo funcionan y la manera en que puede ayudar.
- Anime y ayude al paciente a que practique las capacidades que ha aprendido durante la rehabilitación.
- Asegúrese que el personal de rehabilitación recomiende actividades que coincidan con los intereses y necesidades de su familiar.
- Infórmese sobre las actividades que el paciente puede hacer solo, las que puede hacer con ayuda, y las que no puede hacer. Entonces, no haga aquello que el paciente pude hacer por sí mismo, ya que cada vez que él/ella realice esta tarea(s) aumentará su sentido de logro.
- Cuide de usted mismo, aliméntese bien, descanse lo suficiente, y trate de tomar tiempo para realizar algunas actividades que disfrute.

Para tener mayor control sobre el proceso de rehabilitación, mantenga información importante sobre éste en un lugar seguro. Una recomendación es mantener un libro de notas con el paciente. En las siguientes hojas se presentan ejemplos delos datos que podría incluir en sus notas. (Páginas 20-21)

## Planes para cuando le den de alta

Los planes para cuando se dé de alta al paciente se inician desde el principio del programa de rehabilitación. En ellos participan el paciente, su familia y el personal de rehabilitación. El propósito de estos planes es que el paciente mantenga los beneficios del programa después de haber sido dado de alta. Los pacientes se dan de alta poco después de haber logrado las metas del programa.

El plan incluye los siguientes elementos:

- Asegurarse que la persona regresará a un lugar de habitación seguro.
- Decidir el tipo de cuidado, asistencia o equipo necesarios.
- Hacer arreglos para los servicios necesarios o de rehabilitación para la casa (tales como visitas por una enfermera y otro profesional visitante [ambulante] capacitado).
- Identificar al médico que quedará a cargo de la salud y necesidades médicas de la persona.
- Determinar quiénes estarán a cargo de cooperar en el cuidado de la persona diariamente en el hogar; y proporcionar la asistencia o capacitación necesarias.
- Ayudar a que el paciente explore posibilidades de empleo, actividades voluntarias, y a guiar un auto (si lo puede y quiere hacer).Ejemplos para las notas sobre el programa de rehabilitación
- Hablar sobre las preocupaciones de tipo sexual (esposo o esposa). Muchas personas que han tenido ataques cerebrales continúan una vida activa sexual satisfactoria.

### Preparar el lugar donde vivirála persona

Muchas personas regresan a sus propias casas después del programa de rehabilitación. Otros necesitan vivir en una institución con profesionales especializados como un asilo, o en un lugar habitacional con asistencia (estos lugares generalmente son departamentos en donde los habitantes cuentan con un grupo de profesionales de asistencia según les sea necesario). La decisión depende de las necesidades de cuidado de la persona y los familiares disponibles para proporcionar el cuidado necesario en casa. La persona que ha padecido un ataque cerebral debe regresar a un lugar que ayude a continuar su proceso de recuperación.

Es importante que la persona regrese a un lugar seguro. Si la persona necesita un lugar nuevo donde vivir, el trabajador social puede ayudar a encontrarlo.

Durante los planes para dar de alta al paciente, es probable que el personal del programa hable sobre e incluso visite el hogar. Pueden recomendar cambios para hacer la casa más segura. Por ejemplo: Cambiar las habitaciones de tal manera que la persona pueda permanecer en el mismo piso y no subir y bajar escaleras; cambiar alfombras sueltas o muebles que pudieran causar caídas; y colocar barandales (barandas) y asientos en las tinas o regaderas.

Es recomendable que el paciente tenga una visita de práctica al hogar antes de regresar definitivamente. Esto ayuda a identificar posibles problemas que se tienen que reparar antes que regrese permanentemente.

### Las decisiones en cuanto al equipo o materiales necesarios

Incluso después de la rehabilitación, algunas personas aún tienen problemas al caminar, mantener el equilibrio, o realizar ciertas actividades de la vida diaria. Existe equipo especial que puede ayudarles, tal como:

- Un bastón. Lo usan cuando caminan. Para las personas que tienen problemas con el equilibrio, existen bastones con tres o cuatro pies.
- Andaderas. Proporcionan más apoyo que un bastón. Existen varios diseños que permiten que las usen personas que sólo las pueden tomar con una mano o que tienen otros problemas para caminar o mantener el equilibrio.
- Aparatos ortopédicos de apoyo para los pies o tobillos. Al mantener el tobillo o el pie en una posición adecuada y proporcionar apoyo para la rodilla, ayudan al individuo a caminar.
- Silla de ruedas. Algunas personas necesitan una silla de ruedas y éstas tienen diferentes diseños y se pueden adaptar a las necesidades y capacidades de cada individuo. Pregunte sobre los diseños que ayudan a las personas que han padecido un ataque cerebral.
- Equipo para ayudar a bañarse, vestirse, y comer. Como barandales y tapetes de tina no deslizantes. Otros tipos de equipo facilitan realizar tareas con sólo una mano; como el velcro para cerrar la ropa; o manteles para la mesa que no se deslicen.
- Equipo de comunicación. Varían desde pequeñas computadoras hasta pizarras de comunicación hechas en casa. La persona, su familia y el personal tienen que decidir cuál es el equipo más adecuado para el paciente. El personal puede dar las recomendaciones en cuanto al mejor equipo, y Medicare o las compañías de seguro de salud pueden cubrir por parte del costo.

### La preparación para las personas a cargo del cuidado diario

Normalmente las personas a cargo de este cuidado son esposos, esposas, hijos(as) adultos, amigos o profesionales que trabajan como cuidadores en casa. Normalmente, sólo una persona está a cargo del cuidado principal, y otros ayudan de vez en cuando. Una parte importante del plan para dar de alta al paciente es que estos individuos conozcan las necesidades de seguridad, físicas y emocionales del paciente, y que estén disponibles el tiempo necesario para proporcionar este cuidado.

Dado que cada persona que ha tenido un ataque cerebral es diferente, tiene diferentes necesidades de cuidado. Estas son algunas de las cosas que pueden hacer:

- Guardar notas sobre los planes para dar de alta al paciente, las instrucciones, y hacer las preguntas necesarias para que todo quede claro.
- Asegurarse que la persona tome todos los medicamentos recetados, y que siga las recomendaciones en cuanto a alimentación, ejercicio, descanso y otras necesidades para mantener la salud.
- Animar a la persona a que practique las capacidades que aprendió durante la rehabilitación.
- Ayudar a la persona a resolver problemas y encontrar nuevas formas de hacer las cosas.
- Ayudar a la persona con las actividades que hacía antes del ataque, como manejar herramientas, abotonarse, tareas domésticas, y actividades sociales o de recreación.
- Si la persona no puede hacerlo por sí misma, ayudarle en su cuidado personal.
- Si la persona tiene problemas del habla, ayudarle a comunicarse. Incluya a la persona en conversaciones, incluso cuando no pueda participar activamente.
- Hacer los arreglos para recibir los servicios de la comunidad necesarios.
- Defender al paciente y sus derechos.

Si usted será la persona a cargo del cuidado diario, piense cuidadosamente sobre lo que le espera. ¿Está preparado para trabajar en la recuperación del paciente? Hable sobre esto con las otras personas en el grupo de cuidado. ¿Cuáles son las necesidades de la persona? ¿Quién puede proporcionar el mejor cuidado? ¿Quién estará a cargo de la responsabilidad de cuidado? ¿Tiene que planificar el cuidado de acuerdo a su horario de trabajo y otras actividades? Durante el programa de rehabilitación, hay tiempo suficiente para considerar todos estos temas y desarrollar un plan adecuado con el personal de cuidado.

## Llegar a casa

### Ajustarse al cambio

Regresar a su hogar, o al nuevo lugar donde vivirá, es un gran cambio para la persona. Así es que usar las capacidades que aprendió durante la rehabilitación puede serle difícil en un ambiente nuevo. Mientras que la persona trata de realizar actividades que hacía en el pasado, pueden surgir nuevos problemas relacionados con el ataque cerebral; así es que durante este período, el paciente y su familia tienen que adaptarse a las nuevas necesidades.

Los ajustes son una carga emocional y física tanto para la persona que proporciona el cuidado como para el paciente. Las nuevas responsabilidades para la persona a cargo del cuidado diario pueden impedirle realizar sus propias actividades favoritas; así es que es importante apoyar, entender y tratar de darle tiempo para que descanse. Cuando la responsabilidad de cuidado sólo cae en un individuo, puede causar mucha tensión. Incluso cuando otros familiares están disponibles para ayudar, los conflictos que surgen en cuanto al cuidado, resultan en tensiones.

El ataque cerebral siempre causa tensión, pero ésta es especialmente alta si sólo un miembro queda a cargo del cuidado, ya que el paciente necesita mucho tiempo y atención. Así es que el resto de la familia tiene que hacer un esfuerzo para apoyar a la persona a cargo del cuidado y tratar de cooperar para aliviar la tensión para todos los participantes.

#### Recomendaciones para reducir la tensión

Las siguientes son recomendaciones para reducir la tensión para la persona que sufrió el ataque y los encargados de su cuidado.

- Mantenga la esperanza, y tome la recuperación de un ataque cerebral día con día.
- Recuerde que adaptarse a las consecuencias de un ataque lleva tiempo. Alégrese por cada pequeño logro, conforme descubre nuevas formas de hacer las cosas.
- Cuidar a un enfermo es algo que se aprende. Con la experiencia, su conocimiento y capacidades irán mejorando.
- Experimente. Hasta que hayan encontrado lo adecuado para ustedes, intente hacer las cosas de la vida diaria de diferentes maneras. Por ejemplo, las maneras en que se comunican, el horario del día, y las actividades de la vida social.
- Haga planes para tener "descansos" de tal manera que no tengan que estar juntos todo tiempo. Esta es una buena oportunidad para que le ayuden familiares y amigos. También pueden buscar actividades para ambos fuera de la casa.
- Pida a familiares y amigos que le ayuden en formas y tareas específicas y pídales que se comprometan a hacerlo. Esto les da la oportunidad de ayudar de maneras significativas.
- Lea sobre personas que han pasado por experiencias similares. Su biblioteca pública tiene libros sobre historias reales de personas que han tenido ataques cerebrales y libros sobre personas que cuidan enfermos.
- Tome parte o integre un grupo de apoyo para supervivientes y quienes les cuidan. Entre los miembros del grupo, pueden encontrar soluciones a problemas comunes y desarrollar amistades.
- Sean bondadosos uno con el otro. Sentirse irritado y frustrado de vez en cuando es natural, pero no alivie estos sentimientos tratando "mal" a la otra persona. Frecuentemente, le ayudará hablar sobre estos sentimientos con un amigo, un profesional de rehabilitación, o los miembros del grupo de apoyo.
- Haga planes para disfrutar nuevas experiencias y no mire atrás. Evite comparar su vida ahora a la que tenía antes del ataque.

### Citas de seguimiento médico

Después que se ha dado de alta al paciente, tendrá citas de seguimiento con un médico o con los profesionales de rehabilitación. El propósito de estas citas es revisar la condición médica de la persona, las capacidades que aprendió durante el proceso de rehabilitación, y la manera en la que la persona y su familia se están adaptando a las nuevas condiciones. El paciente y la persona a cargo de su cuidado deben estar preparados para estas citas con una lista de sus preocupaciones y preguntas.

## Dónde obtener asistencia

Existen muchas fuentes y recursos de asistencia. Algunos de éstos son:

- Información sobre ataques cerebrales. Un buen lugar para iniciar su búsqueda son los libros y folletos disponibles a través de organizaciones nacionales que cuentan con información sobre este tema. Muchos de los materiales son gratuitos. Hay una lista de organizaciones en la página 30.
- Grupos de apoyo o clubs para pacientes de ataques cerebrales. En estos grupos, las personas que han sufrido un ataque y sus familias pueden compartir sus experiencias, ayudarse a resolver problemas y ampliar su vida social.
- Servicios de la salud en el hogar. Disponibles a través de la "Visiting Nurses Associations (VNA)", los departamentos de salud locales, departamentos de cuidado en el hogar de hospitales, y agencias privadas. Pueden incluir cuidado de enfermería, terapias de rehabilitación, cuidado personal (por ejemplo, para bañarse y vestirse), cuidado de alivio al cuidador (alguien se queda con el paciente, mientras que la persona que normalmente le cuida toma un descanso), labores del hogar, y otros tipos de ayuda.
- Comidas ambulantes "Meals on Wheels". Se distribuyen comidas calientes a los hogares de las personas que no pueden salir de compras o cocinar.
- Cuidado diurno de adultos. Las personas que no pueden ser totalmente independientes a veces pasan el día en un centro de cuidado diurno. Ahí comen, participan en actividades sociales y pueden recibir ciertos servicios de cuidado médico y de rehabilitación.
- Un compañero visitante. Un compañero pagado o voluntario que hace visitas regulares y llama por teléfono a las personas incapacitadas.
- Servicios de transportación. La mayoría de los autobuses públicos cuentan con una rampa para subir una silla de ruedas. Algunas organizaciones y comunidades cuentan con vehículos especiales que permiten transportar a personas en sillas de ruedas a sus mandados tales como ir de compras o visitar al médico.

Muchas comunidades cuentan con organizaciones de servicio que pueden ayudar y proveen servicios con costos apropiados al ingreso y recursos del individuo, o son gratuitos. Encontrar estos servicios lleva esfuerzo, así es que puede pedir asistencia de los trabajadores sociales que estuvieron a cargo del paciente durante el proceso de rehabilitación. También consulte con el "United Way" y su iglesia, o las páginas amarillas bajo las palabras "Health Services" (servicios de salud), "Home Health Care" (cuidado en casa), "Senior Citizen Services" (servicios para ancianos), o "Social Service Organizations" (organizaciones de servicio social). Simplemente hablar con sus amigos podría proporcionarle información útil, mientras más pregunte, más lejos llegará.

## Otros recursos

Para aprender más sobre la rehabilitación de los ataques cerebrales, y cómo tolerar los efectos de éstos, puede solicitar ayuda de (pregunte si cuentan con asistencia y publicaciones en español):

- ACTION
- 1100 Vermont Avenue, NW
- Washington, DC 20525
- (202) 606-4855 (llame para que le den números regionales)
- Patrocina programas voluntarios para los americanos ancianos.

- Administration on Aging
- 330 Independence Avenue, SW
- Washington, DC 20201
- Gratis (800) 677-1116 (llame para una lista de servicios de ayuda a ancianos en su área)

- AHA Stroke Connection (antes the Courage Stroke Network) American Heart Association
- 7272 Greenville Avenue
- Dallas, TX 75231
- Gratis (800) 553-6321 (o busque en el directorio para el número local de AHA)
- Proporciona información sobre prevención, diagnóstico, tratamiento y rehabilitación para pacientes y sus familias.

- American Dietetic Association/ National Center for Nutrition and Dietetics
- 216 West Jackson Boulevard
- Chicago, IL 60606
- Gratis (800) 366-1655 (Consumer Nutrition Hotline)
- La persona puede hablar con un especialista en dietética y recibir respuestas a sus preguntas sobre nutrición, o puede obtener referencias para un especialista en dietética en su área.

- American Self-Help Clearinghouse St. Clares-Riverside Medical Center
- Denville, NJ 07834
- (201) 625-7101 (pida el número del centro de información estatal o local)
- Proporciona información y asistencia sobre grupos de apoyo.

- National Aphasia Association
- P.O. Box 1887
- Murray Hill Station
- New York, NY 10156
- Gratis (800) 922-4622
- Proporciona información sobre la incapacitación parcial o total del habla o de comprensión del lenguaje hablado que ha resultado de un ataque cerebral u otras causas.

- National Easter Seal Society
- 230 West Monroe Street, Suite 1800
- Chicago, IL 60606
- (312) 726-6200 (o busque Easter Seal Society en el directorio local)
- Proporciona información y servicios para las personas con incapacitaciones.

- National Stroke Association
- 8480 East Orchard Road, Suite 1000
- Englewood, CO 80111
- (303) 771-1700; Gratis (800) STROKES (787-6537)
- Sirve como un centro de información sobre los ataques cerebrales. Ofrece información para formar grupos o clubs de personas que han sufrido ataques cerebrales.

- Rosalynn Carter Institute Georgia Southwestern College
- 600 Simmons Street
- Americus, GA 31709
- Proporciona información sobre el cuidado de enfermos. Listas de lecturas, productos de video y otros recursos para cuidadores. Lo puede obtener todo escribiendo a esta dirección.

- Stroke Clubs International
- 805 12th Street
- Galveston, TX 77550
- (409) 762-1022 (llame para que le den información sobre los grupos en su área)
- Tiene una lista de más de 800 clubs de apoyo en los Estados Unidos.

- The Well Spouse Foundation
- P.O. Box 801
- New York, NY 10023
- (212) 724-7209; Gratis (800) 838-0879
- Proporciona apoyo para esposos, esposas y compañeros de personas con incapacitaciones crónicas.

### Información de Medicare

- Consumer Information Center
- Department 59
- Pueblo, CO 81009

De esta dirección puede recibir una copia de "The Medicare Handbook" que se actualiza cada año. Proporciona información sobre los beneficios de Medicare, suplementos de seguro de salud de Medicare, y los límites de covertura de Medicare. Disponible en español.

## Para más información

La información en esta publicación está basada en Post-Stroke Rehabilitation. Clinical Practice Guideline, Number 16. Se desarrolló por un panel de expertos patrocinados por la "Agency for Health Care Policy and Research (AHCPR)", una agencia del Servicio de Salud Pública. Existen, y se están desarrollando, otras guías en español e inglés sobre diferentes problemas de salud comunes.

Existen otras 4 guías de AHCPR, disponibles en español que le podrían interesar como paciente de un ataque cerebral o quien cuida a uno:

- La prevención de las llagas por contacto: guía para el paciente (en español) que proporciona detalles sobre la prevención de esta condición (AHCPR Publication No. 93-0014).
- Tratamientos para las llagas por contacto: guía para el paciente (en español) describe diferentes tipos de tratamiento para las llagas por contacto. (AHCPR Publication No. 95-0655).
- La incontinencia urinaria en los adultos: guía para el paciente (en español) que describe el por qué de este problema y cómo prevenir las llagas por contacto si padece de esta condición (AHCPR Publication No. 92-0089).
- La depresión es una enfermedad para la que existen tratamientos: guía para el paciente (en español) que presenta información sobre los desórdenes depresivos mayores, que se pueden tratar con éxito con la ayuda de profesionales de la salud (AHCPR Publication No. 93-0554).

Para más información sobre las Guías para el paciente o para recibir copias de esta publicación, llame gratis al 800-358-9295 o escriba a:

- Agency for Health Care Policy and Research
- Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907

## Ejemplos para las notas sobre el programa de rehabilitacion

Metas de rehabilitacion:

________________________________________________________________

________________________________________________________________

________________________________________________________________

Nombre, telefono, especialidad de cada persona que participa en el cuidado y tratamiento del paciente:

________________________________________________________________

________________________________________________________________

________________________________________________________________

Itinerario de actividades de rehabilitacion:

________________________________________________________________

________________________________________________________________

________________________________________________________________

Instrucciones de tratamiento:

________________________________________________________________

________________________________________________________________

________________________________________________________________

Las metas del paciente o las actividades que se han planificado para la semana. (Marque las actividades que ya se han realizado y las metas que se han logrado.):

________________________________________________________________

________________________________________________________________

________________________________________________________________

Otros logros de cada dia (incluyendo pequenos pasos de progreso para llegar a lograr las metas):

________________________________________________________________

________________________________________________________________

________________________________________________________________

Preguntas y preocupaciones sobre las que quiere hablar con el personal de cuidado:

________________________________________________________________

________________________________________________________________

________________________________________________________________