# Información sobre los problemas agudos de la parte baja de la espalda

## Los problemas de la espalda

Como puede ver en el Dibujo 1, la columna vertebral (espina dorsal) está compuesta de pequeños huesos llamados vértebras. Las vértebras se encuentran colocadas una sobre otra formando la columna y, entre cada par de ellas, existe un disco que funciona como un cojín (amortiguador). Las vértebras se mantienen unidas con ligamentos, y los músculos se ligan a las vértebras con unas tiras de tejido conocidas como tendones.

La parte central de cada vértebra es hueca y, en línea con las demás vértebras, forman un canal largo en donde se encuentra la médula espinal. La médula espinal va desde la base del cerebro hasta la parte baja de la espalda. Los nervios de está se ramifican y salen de la columna a través de los espacios entre las vértebras.

La parte baja de la espalda sostiene la mayor parte del peso del cuerpo, de tal manera que incluso un problema menor con los huesos, músculos, ligamentos o tendones del área puede causar dolor cuando la persona está de pie, se inclina, o se mueve. Menos frecuentemente, un problema con el disco puede pellizcar o irritar un nervio de la médula espinal y causar dolor de ciática; que se siente en la pierna hasta debajo de la rodilla.

La columna vertebral y los músculos de la espalda

## Proposíto

Esta publicación trata sobre los problemas agudos de la parte baja de la espalda en los adultos. Si usted padece de estos problemas, puede ser que sus síntomas incluyan:

- Dolor o molestia en la parte baja de la espalda.
- Dolor o adormecimiento (falta de sensación) que le baja a través de la pierna (ciática).

Los problemas de la parte baja de la espalda le pueden impedir realizar sus actividades diarias o realizar las actividades que usted disfruta.

Un problema de la parte baja de la espalda se puede presentar de súbito o gradualmente. Se define como agudo si dura un período corto de tiempo, normalmente de unos días a varias semanas. Un problema de la espalda que dura más de 3 meses ya no se define como agudo.

Si la parte baja de su espalda le ha dado problemas, usted no es el único. Ocho de cada 10 adultos presentarán uno de estos problemas en algún momento de sus vidas y, la mayoría de ellos tendrá más de un episodio que se defina como un problema agudo de la parte baja de la espalda. Entre episodios, las personas vuelven a su rutina normal de vida con pocos o ningún síntoma.

Esta publicación le dará más información sobre los problemas agudos de la parte baja de la espalda, lo que puede hacer, y lo que puede esperar si visita a un médico u otro especialista de la salud.

## Causas de los problemas de la parte baja de la espalda

En muy pocos casos los expertos pueden encontrar la causa exacta de los problemas de la parte baja de la espalda. En la mayoría de los casos, los síntomas se atribuyen a tono muscular deficiente en la espalda, tensíon o espasmo muscular, torceduras de la espalda, desgarramientos de los músculos o los ligamentos, o problemas de las coyunturas (articulaciones). A veces los nervios de la médula espinal se irritan debido a un disco "desviado" y esto causa dolor en la nalga o la pierna. También puede causar adormecimiento, hormigueo (picazón), o debilidad en las piernas.

Las personas que tienen una mala condición física y trabajan en áreas que requieren esfuerzo físico pesado, o pasan períodos prolongados de tiempo sentados o parados, tienen mayor riesgo de padecer de problemas de la parte baja de la espalda. La tensíon emocional o los largos períodos de inactividad física hacen que los problemas de la espalda parezcan peores.

Los problemas de la parte baja de la espalda frecuentemente son dolorosos. Sin embargo, los pacientes raramente tienen una condición médica grave o problemas serios con los huesos o coyunturas de la espalda.

## Lo que puede hacer para sus problemas de la parte baja de la espalda

### Visite al médico o especialista de salud

Muchas personas que presentan una molestia menor en la parte baja de la espalda no visitan al médico de inmediato. Frecuentemente los problemas desaparecen dentro de unos días, sín necesidad de tratamiento. Sin embargo, visite al médico:

- Si los síntomas son severos.
- Si el problema le impide realizar las actividades normales de cada día.
- Si el problema no desaparece en unos días.

Llame al médico de inmediato si también tiene problemas en el control de su orina o excremento, si siente adormecimiento en la ingle (entrepierna) o el recto, o si tiene una debilidad severa de la pierna.

Su médico le examinará para ver si la causa de su problema de la espalda es una condición médica (lo más probable es que este no sea el caso). El médico le ayudará a obtener alivio de los síntomas.

El hará lo síguiente:

- Hablará con usted sobre sus síntomas y las actividades que éstos le impiden realizar.
- Le preguntará sobre sus antecedentes de salud.
- Le hará un examen físico.

### Hable sobre sus síntomas

El médico hablará con usted sobre su problema de la parte baja de la espalda. Las siguientes preguntas son ejemplos de lo que probablemente le preguntará. Puede escribir las respuestas aquí para estar preparado.

¿Cuándo empezaron sus síntomas?
¿Cuáles actividades le impiden realizar las molestias de su espalda?
¿Hay algo que usted hace que mejora o empeora sus síntomas?
¿Tiene algún problema con sus piernas?
Al mismo tiempo que se iniciaron los síntomas, ¿tuvo fiebre, o dolor o quemazón (ardor) al orinar?

### Hable sobre sus antecedentes de salud

Asegúrese de informarle al médico sobre su estado general de salud y sobre las enfermedades que ha tenido en el pasado. Las siguientes son algunas preguntas que probablemente le hará el médico sobre sus antecedentes de salud. Puede escribir las respuestas aquí para estar preparado.

¿Ha tenido algún problema de la espalda en el pasado? Si es así ¿cuándo?
¿Cuáles enfermedades ha tenido en el pasado (por ejemplo, cáncer, artritis, o enfermedades del sistema inmune)?
¿Qué medicamentos toma regularmente?
¿Alguna vez ha usado drogas ilegales en forma intravenosa (que se inyectan en la vena)?
¿Ha bajado de peso recientemente, sín haber estádo a dieta?

También dígale al médico sobre lo que ha hecho para tratar de aliviar sus síntomas o molestias: los medicamentos que ha tomado, cremas o ungüentos que ha usado, o cualquier otro remedio casero.

### El examen físico

Su médico le examinará la espalda. Incluso un examen médico cuidadoso probablemente no indicará la causa exacta se su problema. Sin embargo, se podrá determinar que su problema no es el resultado de una condición médica grave. Esto sólo sucede en 1 de cada 200 pacientes. Si ha tenido su problema de la espalda por sólo unas semanas, es probable que no necesite otros exámenes médicos especiales (vea la página 11).

## Obtener alivio

El médico le ayudará a obtener alivio del dolor, molestia u otros síntomas. Existen muchos medicamentos y otros tratamientos que le pueden ayudar con los síntomas de la parte baja de la espalda. Las buenas nuevas son que la mayoría de los pacientes sienten mejoría pronto.

### Tratamientos comprobados

Los medicamentos ayudan a aliviar los síntomas. El tipo de medicamento que le recomendarán depende de los síntomas y el nivel de molestia que le causan.

- Si sus síntomas son de leves a moderados, probablemente le aliviarán los medicamentos que puede obtener sin necesidad de receta médica, como el acetaminofén, la aspirina, o el ibuprofén. Estos médicamentos causan menos efectos secundarios (molestias) que los medicamentos de receta médica y son menos costosos.
- Si sus síntomas son severos, probablemente le darán medicamentos de receta.

En la mayoría de los casos los medicamentos ayudan a controlar el dolor y las molestias, pero todos los medicamentos tienen efectos secundarios. Por ejemplo, algunos pacientes no pueden tomar aspirina o ibuprofén porque les causan irritación estomacal e incluso úlceras. Muchos medicamentos de receta para el dolor de la espalda le pueden hacer sentirse somnoliento (con sueño). No se deben tomar si usted guía un vehículo o maquinaria pesada. Hable con el médico sobre los beneficios y desventajas de cualquier medicamento que le recomiende. Llame al médico de inmediato si tiene efectos secundarios (como náusea, vómito, irritación de la piel, o mareo) causados por el medicamento. Si éste es el caso, suspenda el uso del medicamento y llame a su médico de inmediato.

Existen otros tratamientos que por sí mismos, o en combinación con los medicamentos, podrían ayudar a aliviar sus síntomas. El médico probablemente le recomendará uno o más de los siguientes:

- Compresas frías o calientes en su espalda. Dentro de las primeras 48 horas desde que se han iniciado los síntomas, probablemente deseará colocar una compresa fría (una bolsa de hielo) en el área del dolor en su espalda por intervalos de 5 a 10 minutos a la vez. Si sus síntomas duran más de 48 horas, probablemente encontrará que un paño caliente (cojín eléctrico) o una ducha o baño caliente le ayudará a aliviar el dolor.
- Manipulación de la columna. Existe cierta evidencia que este tratamiento (que consiste en ejercer presíon con las manos en la columna para ÓajustarlaÔ) ayuda a algunos pacientes con dolor en la parte baja de la espalda durante el primer mes que se presentan las molestias. Sólo lo debe hacer un profesional de salud con capacitación en este tipo de tratamiento. Debe ir a ver al médico si los síntomas no han mejorado después de 4 semanas de este tratamiento.

Recuerde que cada paciente es diferente y que usted mismo tendrá que encontrar los tratamientos que funcionen mejor en su caso y para sus síntomas.

### Otros tratamientos

También se usan muchos otros tratamientos para esta condición. A pesar que éstos probablemente proporcionan alivio temporal, ninguno de ellos ha comprobado ser más eficaz en la curación, o hacerla más rápida, o impedir que se repitan los síntomas. Además, pueden ser costosos. Estos incluyen:

- Tracción.
- La estimulación electrónica transcutánea de los nervios (TENS-transcutaneous electrical nerve stimulation).
- Los masajes.
- La biorretroalimentación ("biofeedback" -- una técnica que le enseña al paciente a controlar el dolor).
- La acupuntura (usar agujas en los nervios).
- Inyecciones en la espalda.
- Fajas y corsetes especiales para la espalda.
- Ultrasonido.

## Actividad física

El médico le preguntará sobre sus actividades físicas diarias (en su trabajo o en casa). Mientras se recupera, el médico probablemente recomendará algunos cambios en sus actividades. Hable con él sobre su situación específica. En general, cuando el dolor es severo, le recomendará que evite:

- Cargar objetos pesados.
- Levantar objetos cuando su cuerpo no está en una posición frontal; cuando está inclinado; o cuando se estira tratando de alcanzar algo.
- Permanecer sentado por demasiado tiempo.

Lo más importante es que pueda regresar a su vida normal lo más pronto posible y cuando ya no hayan riesgos. Usted, el médico y su patrón (si trabaja) deben decidir lo que puede y no puede hacer sin riesgo y cuándo puede regresar al trabajo. Su horario puede ir aumentando gradualmente conforme mejore su espalda.

Posición correcta para levantar y cargar objetos

## Reposo en cama

Si sus síntomas son severos, su médico probablemente le recomendará que se quede en cama. Sin embargo, el reposo en cama se debe limitar a 2 o 3 días. Quedarse acostado por períodos más largos puede debilitar los músculos y los huesos y hacer más lenta su recuperación. Si siente que tiene que permanecer en cama, asegúrese de pararse en unas horas y caminar, incluso si le duele. Sentir un poco de molestias conforme vuelve a su vida normal no quiere decir que se esté causando daño.

## El trabajo y su familia

Los problemas de la espalda tardan en mejorarse. Si su trabajo y sus actividades de la vida diaria hacen que sus síntomas empeoren, es importante que se lo informe así a sus familiares, supervisores o compañeros de trabajo. Concentre su energía en realizar las tareas que no le causen molestias tanto en casa como en el trabajo. Sea productivo, pero también tiene que ser firme y hablar sobre las actividades que no puede realizar.

## Lo que puede hacer ahora

Mientras espera mejoría, puede tratar de estar más cómodo:

- Usando zapatos sin tacón y cómodos.
- Asegurándose que su mesa de trabajo se encuentre a una altura adecuada para su estatura.
- Usando una silla que le brinde apoyo para la parte baja de la espalda y que se pueda reclinar un poco.
- Si tiene que estar sentado por largos períodos de tiempo, colocando sus pies en el suelo o en un banquito, lo que le sea más cómodo.
- Si tiene que estar de pie por períodos largos de tiempo, tratando de colocar uno de sus pies en un banquito bajo.
- Si debe guiar un vehículo por largas distancias, tratando de usar una almohada o una toalla enrollada en la parte baja (curva) de su espalda.
- Si tiene problemas para dormir, tratando de dormir boca arriba con una almohada bajo sus rodillas; o durmiendo de lado, con las rodillas dobladas y una almohada entre las rodillas.

## Ejercicio

Se recomienda que usted regrese gradualmente a las actividades normales de su vida, incluyendo el ejercicio. El ejercicio es importante para su salud general y puede ayudarle a bajar de peso (si es necesario). Incluso si sus síntomas son de moderados a leves, puede realizar las siguientes actividades físicas sin lastimar o tensionar su espalda:

- Caminar distancias cortas.
- Usar una bicicleta fija.
- Nadar.

Es importante que empiece cualquier tipo de programa de ejercicio lentamente y que, poco a poco, aumente la velocidad y el período de tiempo que hace ejercicio. En un principio probablemente notará que sus síntomas empeoran un poco cuando hace ejercicio o realiza más actividades. Normalmente esto no es causa para preocuparse. Sin embargo, si el dolor se hace severo, llame al médico. Una vez que se sienta agusto con sus actividades normales, el médico probablemente le recomendará más ejercicio de tipo aeróbico y ejercicios especiales para la espalda.

## Si no se mejora

La mayoría de los problemas de la parte baja de la espalda se mejoran rápido, normalmente en un período de 4 semanas. Si sus síntomas no mejoran en este tiempo, debe de volver a llamar al médico.

### Exámenes especiales

El médico le volverá a examinar y le hablará sobre algunos exámenes médicos especiales. Estos pueden incluir rayos-x, analisís de sangre y otros exámenes especiales como las imágenes por resonancia magnética (en inglés MRI-magnetic resonance imaging), o una tomografía computada (en inglés CT -- computerized tomography). Estos probablemente le ayudarán al médico a determinar la razón por la que no mejora. Probablemente decida darle una referencia para que visite a un médico especialista en problemas de la espalda.

Ciertas situaciones, como la tensíon emocional en el trabajo o en el hogar, problemas personales o emocionales, depresión, o problemas con el alcohol o las drogas, pueden hacer más lenta su recuperación, o hacer que los síntomas le parezcan peores. Si tiene cualquiera de estos problemas, hable con su médico.

## La cirugía

Incluso el tener mucho dolor de espalda no quiere decir que necesite una operación. Se ha determinado que la cirugía de la parte baja de la espalda sólo ayuda a 1 de cada 100 pacientes. En algunas personas, la cirugía puede incluso causar más problemas. Esto es especialmente cierto para las personas cuyo único síntoma es el dolor.

La mayoría de los pacientes que requieren cirugía tienen ciertos problemas con los nervios o condiciones tales como fracturas o dislocaciones. En la mayoría de los casos, sin embargo, la decisíon de operar no se tiene que tomar de inmediato; ya que la condición no empeora si se espera por varias semanas.

Si el médico recomienda una operación, asegúrese de preguntar la razón por lo que la recomienda y pida que le explique los beneficios y posibles desventajas. Probablemente también le convenga pedir una segunda opinión de otro médico.

## La prevención de los problemas de la parte baja de la espalda

La mejor manera de prevenir los problemas es mantenerse en buena condición física. Si tiene que levantar objetos, incluso después que se haya mejorado, tiene que:

- Mantener el objeto cerca de su cuerpo.
- Evitar levantar algo mientras no esté en una posícion frontal, o cuando esté inclinándose, o estirándose para alcanzar algo.

Debe seguir haciendo ejercicio incluso después que hayan desaparecido los síntomas. Existen muchos ejercicios que ayudan a mejorar la condición de los músculos del cuerpo y de la espalda. Debe hablar con su médico sobre los ejercicios que más le beneficiarían.

## Cuando se vuelven a presentar los síntomas

Más de la mitad de las personas que se recuperan de un episodio de síntomas agudos de la parte baja de la espalda volverán a sufrir otro episodio dentro de los siguientes años. A menos que los síntomas sean muy diferentes a los que presentó la primera vez, o si tiene alguna otra condición de salud, es probable que también se recupere completamente de cada nuevo episodio.

## Mientras se recupera su espalda

Es importante que recuerde que incluso si tiene un problema con su espalda en este momento, lo más probable es que mejorará pronto. Recuerde que usted mismo es la persona más importante en el cuidado de su espalda y en lograr recuperarse y volver a realizar sus actividades normales.

También le ayudará recordar que:

- La mayoría de los problemas de la parte baja de la espalda duran por períodos cortos de tiempo y mejoran con poca o ninguna intervención médica o tratamiento.
- Los problemas de la espalda pueden ser dolorosos, pero esto no quiere decir que su espalda a sufrido un daño severo.
- El ejercicio le puede ayudar a sentirse mejor más rápido y a prevenir más problemas de la espalda. Un programa regular de ejercicio es bueno para su salud en general y le puede ayudar a recuperarse y reanudar su vida normal.

## Para obtener más información

La información en esta publicación se obtuvo de "Clinical Practice Guideline, Acute Low Back Problems in Adults." La guía fue escrita por un panel de expertos del sector no gubernamental patrocinado por la Agency for Health Care Policy and Research. Existen y se están desarrollando otras guías en inglés y español sobre diversos temas de salud de interés para el público.

Para más información sobre las guías y para obtener copias gratuitas de esta guía, llame al: 800-358-9295, O escriba a:

- Agency for Health Care Policy and Research
- Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907

Nota:La ilustración del Dibujo 1 se tomó de otra publicación patrocinada por AHCPR titulada, Back in Action.