# Lo que la mujer debe saber sobre los mamogramas (rayos-x del seno)

## ¿Qué es un mamograma?

Los mamogramas son rayos-x (radiografías) de los senos que se toman con un nivel bajo y seguro de radiación.

El procedimiento durante el cual se toman los mamogramas se llama mamografía. Existen dos tipos de exámenes de mamografía: La exploratoria (investigacional) y la diagnóstica.

El mamograma exploratorio es una forma rápida y sencilla de detectar el cáncer del seno en sus etapas tempranas, cuando los tratamientos son más eficaces y el nivel de supervivencia es alto. Generalmente se toman dos radiografías de cada seno y un médico especializado en interpretar estas imágenes (radiólogo) las examina.

Los expertos están de acuerdo de que la mamografía exploratoria ayuda a reducir el índice de muertes por cáncer del seno entre las mujeres mayores de los 50 años. Existen opiniones diversas, sin embargo, en cuanto al valor de este procedimiento para las mujeres menores de los 50 años.

Hágase un mamograma exploratorio tan frecuentemente como lo recomiende su médico. Este tipo de mamograma puede mostrar cambios en los senos, como masas (quistes o tumores), mucho antes que éstos se puedan detectar (encontrar) en una palpación (sentirlos con los dedos).

El mamograma diagnóstico es indicado cuando pudiera haber un problema. También se usa cuando es difícil obtener una imagen clara del seno debido a circunstancias especiales (por ejemplo, entre las mujeres que tienen implantes en los senos). La mamografía diagnóstica lleva más tiempo porque se tienen que tomar más radiografías. Es probable que el radiólogo revise estas radiografías mientras que usted espera.

## El propósito de esta publicación

Esta publicación le ayudará a aprender más en cuanto a cómo obtener el mejor mamograma disponible. Estar bien informada sobre este proceso le ayudará a cooperar con el equipo de profesionales de la salud a cargo de su cuidado antes, durante y después de hacerse un mamograma. Así obtendrá los resultados más precisos y un servicio de calidad.

Existen muchos profesionales de la salud que pueden participar en su cuidado de detección del cáncer del seno. Entre ellos: Médicos, enfermeras, enfermeras practicantes y practicantes médicos (éstos dos ultimos han sido capacitados para realizar ciertas tareas profesionales, pero no son titulados). Ellos pueden estar a cargo de examinar sus senos, darle una referencia para obtener una mamografía, y ayudarle a obtener otros exámenes si éstos son necesarios. En esta publicación usaremos el término "médico" para facilitar su lectura, pero esta palabra puede indicar a cualquiera de los profesionales que se han mencionado, quienes le pueden proporcionar el cuidado adecuado.

En el centro de mamografía, tanto la persona que toma las radiografías (técnico en radiología), como el radiólogo y las personas encargadas de calibrar y mantener las máquinas funcionando adecuadamente, han recibido capacitación especializada en mamografía. Ellos trabajan como un grupo de cuidado para asegurar que le darán servicios de la mejor calidad.

Después de hacerle los mamogramas, su médico recibirá los resultados. Asegúrese de solicitar los resultados del mamograma de su médico o del centro de mamografía.

También asegúrese que entiende los resultados del examen y cualquier recomendación para realizar otros exámenes de seguimiento. Sobre todo, nunca deje de hacer todas las preguntas que tenga.

Los siete pasos que le presentamos a continuación le pueden ayudar a vigilar su salud y detectar posibles problemas en sus senos. Tiene que ser responsable de seguir todos los pasos.

## Los siete pasos para detectar el cáncer del seno en sus etapes tempranas

### 1. Hágase exámenes regularmente

Este es el paso más importante para detectar cualquier problema en sus senos.

- Hágase un examen profesional (con un médico) de los senos durante su visita de revisíon regular.
- Hágase un mamograma con la frecuencia que recomiende su médico. Pregúntele cuándo debe hacerse el siguiente mamograma.
- Hágase un autoexamen de los senos cada mes. Su médico le puede indicar cómo hacerlo.

Estos tres exámenes pueden ayudar a usted y a su médico a establecer lo que es normal y anormal en sus senos y, por lo tanto, a distinguir todos aquellos síntomas de posibles problemas.

Llame al médico si nota lo siguiente:

- Una masa o engrosamiento (tejido denso) en el seno.
- Secreción de los pezones que llegue a mojar su sostén o las sábanas.
- Cambios en la apariencia de la piel del seno.

Estos cambios pueden ser normales, pero es importante que se haga revisar por el médico lo más pronto posible.

### 2. Elija un centro de mamografía de alta calidad

La mamografía se puede realizar en muchos hospitales, clínicas y centros de radiología. Las unidades móviles (generalmente ubicadas en autobuses especiales) proporcionan mamografías en lugares como centros comerciales, centros comunitarios, oficinas y fábricas. Todos estos centros deben cumplir con los mismos requisitos de calidad.

Su médico le puede recomendar un centro de mamografía, o usted puede elegir el que le quede más conveniente.

Pero antes de elegir un centro de mamografía, averigüe si cuenta con certificación de la "Food and Drug Administration (FDA)" (la administración a cargo de vigilar la calidad de los alimentos y medicamentos en los Estados Unidos). Si es una unidad de la "Veterans Health Administration (VHA)" (la administración de veteranos), está ya cuenta con certificación.

Una nueva ley llamada "Mammography Quality Standards Act" exige que todos los centros de mamografía hayan sido certificados a partir del primero de octubre de 1994. La VHA cuenta con su propio programa de certificación similar al de la FDA. Para obtener la certificación, los centros de mamografía, su maquinaria, empleados y registros deben cumplir con los requisitos necesarios.

Si el centro al que vaya no tiene certificación de la FDA, elija otro centro que sí la tenga.

Para encontrar un centro de mamografía certificado hable con su médico o llame gratis al Servicio de Información sobre el Cáncer del Instituto Nacional del Cáncer al 1-800-422-6237 (este servicio cuenta con personal que habla español).

Cuando vaya al centro de mamografía busque el certificado que compruebe que el centro ha sido certificado por la FDA. Este certificado debe estar colocado en un lugar que le permita leerlo con facilidad.

### 3. Haga la cita para el mamograma en el momento del mes en el que sus senos estén menos sensibles

Durante la mamografía, los senos se presionan entre dos láminas de plástico por unos pocos segundos. Esta presíon permite obtener una imagen clara del seno usando niveles muy bajos de radíacion. Esto puede ser molesto, y algunas mujeres dicen que les duele.

Si sus senos son sensibles al tacto, trate de hacer su cita en el momento del mes cuando estén menos sensibles. Por ejemplo, evite hacer la cita la semana anterior a su menstruación (regla), ya que en ese momento puede sentir mayor molestia.

### 4. Proporcione y obtenga toda la información al hacer la cita para su mamograma

Cuando llame para hacer la cita (si no habla inglés pida a una pariente o amiga que le ayude), esté preparada a proporcionar la información requerida por el centro de mamografía. También le pueden hacer más preguntas cuando llegue a su cita, así es que le ayudará llevar consigo toda la información que tenga. Estos datos incluyen:

- Su nombre, dirección y teléfono.
- Su edad.
- Nombre, dirección y teléfono de cualquier otro centro de mamografía donde le hayan hecho un mamograma en el pasado.
- Si alguien en su familia ha tenido enfermedades del seno (cáncer).
- Cualquier problema con sus senos y por cuánto tiempo lo ha tenido.
- problemas con sus senos en el pasado, biopsias del seno, o cirugías del seno.
- Si tiene implantes en los senos.
- Otra información personal:
  - Si está embarazada o dándole el pecho a un niño.
  - Las fechas de su menstruación, o la fecha en que empezó su menopausia (dejar de menstruar).
  - Cualquier cosa que podría hacer difícil tomarle un mamograma (por ejemplo, que sus senos sean muy grandes, o que no se pueda sostener en pie).
- Nombre, dirección y teléfono de su médico.

Estas son algunas de las preguntas que usted debe hacer antes de la cita para el mamograma:

- Cómo, cuándo y de que manera se le darán los resultados del mamograma.
- Lo que tiene que hacer para prepararse a que le tomen un mamograma. (Lea las páginas 8-9 de esta publicación para más detalles sobre este punto.)

Si tiene otras preguntas antes del mamograma, llame a su médico o al centro de mamografía.

### 5. Conozca lo que sucederá durante el procedimiento

Entender lo que sucederá durante el mamograma le ayudará a reducir los niveles de ansiedad que pudiera tener. Es importante que sepa que el nivel de radíacion que se usa durante la mamografía es muy bajo.

Cuando le hacen un mamograma usted se para en frente de una máquina especial de rayos-x. El técnico en radiología coloca el seno en una placa que contiene la película para la radiografía. Esta placa se puede subir o bajar de acuerdo a su estatura.

Gradualmente, el seno se presiona contra otra placa transparente especial. Se necesita presionar el seno mientras se toman las radiografías para obtener imágenes claras. La presíon no dañara su seno. De hecho, el presionar el seno permite reducir la cantidad de radíacion necesaria para la radiografía.

Los estudios muestran que la mayoría de las mujeres no sienten dolor durante el mamograma. Trate de estar tranquila y, si siente que la presíon en el seno le molesta demasiado, dígale al técnico que mueva las placas para reducir la presíon.

Si existe un área específica de su seno que parece tener un problema, el radiólogo o el técnico en radiología probablemente lo examinarán.

### 6. Vaya preparada

- Vístase con dos piezas; de tal manera que sólo se tenga que quitar la blusa para el mamograma.
- No use desodorante, talco, o cremas en las axilas o cerca de los senos el día del mamograma. Estos productos pueden salir en la radiografía.
- Lleve consigo el nombre, dirección y teléfono de su médico.
- Lleve consigo una lista de los lugares y fechas de las mamografías, biopsias, y otros tratamientos al seno que le hayan hecho en el pasado.
- Pida a los centros de mamografía en donde le hicieron mamogramas en el pasado que le presten los mamogramas y llévelos consigo, si esto es posible. El nuevo mamograma se puede comparar con el anterior para buscar cualquier cambio.

También le ayudará:

- Llevar consigo una lista de sus preguntas sobre la mamografía y los mamogramas que le tomarán.
- Llevar consigo a alguien que le ayude a comunicarse con el personal del centro, especialmente si usted no habla inglés.
- Si teme que el mamograma le causará molestias, tome un medicamento contra el dolor una hora antes de su cita. Esto no afectará en nada el mamograma.

Si hay algo que no entiende, haga preguntas. Insista en hacer sus preguntas hasta que entienda las respuestas claramente.

### 7. Siga todos los pasos necesarios después del mamograma

Obtener los resultados de su mamograma es muy importante.

Lo más probable es que los resultados de su mamograma sean normales. Es muy importante, sin embargo, que usted no crea que todo está bien sólo porque no ha recibido los resultados. Si no ha recibido los resultados 10 días después del examen, pregunte a su médico, o llame al centro de mamografía usted misma. [image]

Si el mamograma exploratorio muestra algo fuera de lo normal, hable con su médico lo más pronto posible para decidir que es lo que se tiene que hacer a continuación. Probablemente le hará una cita para un mamograma diagnóstico, o usted misma puede hacer la cita; pero hágalo lo más pronto posible. Hable con el médico sobre los resultados.

Cuando los resultados del mamograma de diagnóstico muestran algo fuera de lo normal, el radiólogo puede recomendar otro examen. La biopsia es un procedimiento en el que se saca un pedacito del tejido del seno para estudiarlo bajo un microscopio. A veces se necesita una biopsia porque su médico encontró algo fuera de lo normal, esto incluso si los resultados del mamograma parecen ser normales.

Si el mamograma muestra un problema o se recomiendan otros pasos, asegúrese de:

- Entender claramente los pasos que se tienen que tomar a continuación.
- Obtener los resultados de cualquier otro examen médico que le hagan a continuación.
- Preguntar todo lo que sea necesario hasta que entienda toda la información.

Si le hacen un mamograma que muestre algo fuera de lo normal y no tiene un médico, tendrá que encontrar a uno para que la atienda. Pida al personal del centro de mamografía que le ayuden a encontrarlo. Inmediatamente haga una cita y hable con él sobre los resultados del mamograma y lo que se tiene que hacer a continuación.

La mamografía es un procedimiento muy eficaz, pero no detecta todos los problemas del seno. Si encuentra algo fuera de lo normal en sus senos, llame inmediatamente a su médico.

Usted es responsable:

- Haga citas para que le hagan un mamograma con la frecuencia que recomiende su médico.
- Obtenga siempre los resultados de sus mamogramas.
- Siga las recomendaciones de su médico si existen pasos de seguimiento y, si es necesario, haga una cita para un mamograma diagnóstico en cuanto sea posible.
- Haga que el médico examine sus senos como parte de su visita regular. Usted hágase un autoexamen de los senos una vez al mes.
- Si tiene una masa o quiste en el seno, o cualquier otro cambio, llame a su médico. Incluso si le han hecho un mamograma recientemente y ha resultado normal.

## ¿Cómo puedo aprender más sobre la mamografía?

La mayoría de los centros de mamografía cuentan con información impresa o videos que proporcionan instrucciones en cuanto a cómo vigilar la salud de sus senos. Léalos y vea los videos cuando vaya a hacerse un mamograma. (Pregunte si tienen esta información en español, si no es así, lleve consigo a una familiar o amiga que le ayude a entender esta información.)

Para información general sobre el cáncer del seno y la mamografía, llame a:

- Servicio de Información sobre el Cáncer ("Cáncer Information
- Service-CIS") que es parte del National Cáncer Institute.
- (Este servicio cuenta con personal que habla
- español)...................800-422-6237
- Food and Drug Administration (FDA)
- MQSA Consumer Inquiries
- 1350 Piccard Lane
- (HFZ-240)
- Rockville, MD 20850
- American Cancer Society........800-277-2345