# Cuando se acumula líquido en el oído medio de su niño

## El oído y su funcionamiento

Como puede observar en el siguiente dibujo, el oído consiste de tres partes: El oído externo, el oído medio, y el oído interno. El oído externo incluye la oreja y el canal del oído. Al final del canal del oído, se encuentra el tímpano, que es una membrana de tejido en forma de círculo y aproximadamente del tamaño de la punta de un dedo. Detrás del tímpano se encuentra un espacio normalmente lleno de aire conocido como el oído medio. Esta es la parte del oído en donde se acumula el líquido cuando existe la condición. El tubito que conecta el oído medio con un pasaje de aire en la parte de atrás de la nariz se llama trompa de Eustaquio. Existen tres pequeños huesos que conectan el tímpano al oído interno a través del oído medio. Finalmente el oído interno es el que se encuentra más adentro de la cabeza y permite que la persona escuche, y también ahí se encuentra el sentido del equilibrio.

En el oído sano, las ondas de sonido se transportan a través del canal del oído y hacen que el tímpano vibre. Esto, a su vez, hace que los tres huesecillos del oído medio se muevan. El movimiento envía las ondas de sonido a través del oído medio hasta que llegan al oído interno. El oído interno envía los sonidos hacia el cerebro y esto permite que la persona escuche los sonidos del mundo externo. Cuando hay líquido en el oído medio, el tímpano no vibra normalmente y puede causar sordera parcial en el niño.

## El propósíto de esta publicación

Esta publicación proporciona información sobre la acumulación de líquido en el oído de los niños entre 1 a 3 años de edad que no tienen ningún otro problema de salud (otitis media con efusíon). Después de leer esta publicación usted sabrá más sobre los siguientes temas:

- Causas de la condición.
- Los exámenes médicos para evaluar la acumulación de líquido en el oído y evaluar su efecto en la capacidad auditiva (de oír).
- Los tratamientos disponibles para aliviar (mejorar) esta condición y la sordera parcial que puede causar.
- La manera en la que puede cooperar con el médico de su niño para encontrar los mejores tratamientos.

La acumulación de líquido en el oído medio también se conoce como otitis media con efusíon. Otitis media quiere decir que hay inflamación en el oído medio, y efusíon quiere decir qué hay acumulación de líquido.

## ¿Qué es la acumulación de líquido en el oído medio?

Si su niño tiene líquido en el oído quiere decir que se le ha acumulado una sustancia mucosa o líquida detrás del tímpano. Muchos niños padecen de esta condición durante sus primeros años de vida. Sin embargo, es importante que sepa que la acumulación de líquido en el oído no es lo mismo que una infección del oído. Las dos condiciones son diferentes:

- Las infecciones del oído normalmente sólo afectan un oído y, cuando su niño las padece, probablemente tendrá mucho dolor de oído y fiebre. Cuando el médico revisa al niño, es posible que observe que el tímpano está hinchado y rojizo, y que hay algo de líquido en el oído medio.
- La acumulation de liquido se presenta en los dos oídos al mismo tiempo y la mayoría de los niños que la padecen no tienen dolor o fiebre. Es necesario hacer un examen médico especial para ver si el niño tiene esta condición (vea las páginas 4 y 5).

## ¿Cuáles son las causas de la acumulación de líquido el oído?

Las siguientes son algunas de las causas de esta condición:

- Haber tenido infecciones del oído en el pasado. Estas infecciones son comunes entre los niños pequeños y a veces resultan en acumulación de líquido en el oído medio.
- Un bloqueo (tapón) en la trompa de Eustaquio (como puede ver en el Dibujo 1.)
- Un resfriado o influenza ("flu").

No existe una causa definitiva que explique la acumulación de líquido en el oído. Frecuentemente, el médico no le podrá dar una respuesta definitiva. La tabla en la página 13 probablemente le ayudará a mantener un historial de cuándo su niño ha tenido problemas del oído y los tratamientos que se le han proporcionado.

[un historial de cuándo su niño ha tenido problemas del oído y los tratamientos que se le han proporcionado]

___________________________________________________________

De (nombre del niño)

___________________________________________________________

Nombre del médico o enfermera a cargo de su cuidado

___________________________________________________________

Teléfono

Fecha y tipo de problema (líquido en el oído medio o infección del oído) | Tratamiento | Resultados

## ¿Por qué debo estar pendiente de esta condición?

Muchos padres y médicos temen que los niños que tienen líquido en uno o ambos oídos pueden tener problemas para oír (sordera parcial). Los expertos no saben hasta qué punto el líquido en el oído afecta la capacidad para oír. Tampoco se sabe si la sordera parcial que causa la condición puede ocasionar problemas para que el niño aprenda a hablar o para que aprenda en la escuela. En otras palabras, aún no se conocen las consecuencias a largo plazo de esta condición.

## ¿Cómo se puede prevenir la acumulación de líquido en el oído?

Estudios científicos recientes indican que los niños que viven con fumadores o que acuden a una guardería infantil ("day care") tienden a tener más infecciones de los oídos. Debido a que algunos de los niños que tienen infecciones de los oídos más tarde tendrán acumulación de líquido en el oído, puede ser que dos formas de prevenir el problema sean:

- Tratar que su niño no esté en un ambiente de fumadores.
- Tratar que su niño no esté en contacto con compañeritos de juego que estén enfermos.

## ¿Cómo puedo saber si mi niño tiene acumulación de líquido en el oído?

Los niños qué tienen acumulación de líquido en el oído a veces no oyen bien. La queja más común de sus padres es que el niño aumenta mucho el volumen de la televisión o se sienta demasiado cerca de ella. A veces, los padres dicen que parece que el niño no presta atención cuando se le habla. Frecuentemente, el problema se detecta durante una visita médica regular. Sin embargo, hable con el médico si nota cualquier problema que tenga el niño para oír. El médico realizar exámenes para diagnosticar la condición.

- El Otoscopio neumático se usa para detectar líquido en el oído (vea el Dibujo 2). Este instrumento se usa para mirar dentro del oído. El líquido se puede ver a través de la membrana del tímpano. Incluso si no se puede ver el líquido, el médico puede soplar aire con el instrumento y ver que tan bien vibra el tímpano. Para poder realizar este examen, el niño no se debe mover y, aunque puede sentir el tubo dentro de su oído, no le causa ningún dolor. Este examen NO evalúa la capacidad auditiva del niño. Muchos médicos opinan que el otoscopio neumático es el mejor instrumento para detectar líquido dentro del oído.
- La Timpanometría es otra forma de determinar el funcionamiento o vibración del tímpano. Durante este examen se introduce un tubo del tamaño de la punta del dedo meñique cubriendo totalmente el canal del oído. Este instrumento se conecta con otro aparato llamado timpanómetro. Mientras que el aparato evalúa la vibración del tímpano, el niño escucha un sonido bajo por un corto tiempo. Cuando hay líquido en el oído, el tímpano vibra menos de lo normal. Al igual que el examen anterior, el niño tiene que quedarse quieto y sentirá el tubo en el oído, pero no le causa dolor. Nuevamente, esté examen NO evalúa la capacidad auditiva.
- El examen de audición evalúa si el niño tiene sordera parcial debida a la condición, pero no sirve para determinar si hay líquido en el oído medio. El tipo específico de examen depende de la edad del niño y su capacidad auditiva.

## ¿Cuáles son los tratamientos para el líquido en el oído?

En nuestros países existen muchos remedios caseros para tratar de curar los problemas de los oídos en los bebés y los niños. Estos remedios pueden incluir: Gotas de té, pasta de albahaca, gotas de glicerina, de limón o de miel de abeja, poner un cono de papel en el oído del niño, y otros. Es importante que le diga al médico o la enfermera si ha usado o si quiere usar éstos o cualquier otro remedio casero. Recuerde que sólo el médico puede recomendar el mejor tratamiento y que algunas veces los remedios caseros pueden dañar en vez de curar a su niño.

Existen varios tratamientos para la condición y es importante que sepa que a veces un tratamiento eficaz para un niño no sirve en otros. Si un tratamiento no es adecuado, se pueden usar otros. Hable con el médico sobre los tratamientos y sus posibles beneficios y desventajas. Decida con él sobre el tratamiento más adecuado para su hijo.

- Observación médica. Frecuentemente el líquido en el oído desaparece sin necesidad de tratamiento. Algunos estudios científicos indican que el líquido desaparece sin tratamiento en un período de 3 a 6 meses.
- Antibióticos. Los estudios científicos muestran que el líquido desaparece un poco más rápido entre los niños que toman antibióticos. Sin embargo, los antibióticos tienen algúnos efectos no deseados cómo diarrea, irritaciones de la piel y otros (vea las páginas 8 y 9). Estos medicamentos pueden ser costosos, y algunos niños tienen problemas al tomarlos. Por estas razones, primero hable con el médico sobre la posibilidad de usar la observación medica sin tratamiento. Finalmente, hablen sobre el costo y los posibles efectos secundarios (molestias) causados por los antibióticos.
- Cirugía para insertar tubos en los oídos. Esta es una cirugía (operación) menor en la que se hace un pequeño corte en el tímpano para cuidadosamente extraer el líquido acumulado en el oído medio. Después se inserta un tubito de metal o de plástico en el tímpano. Para realizar esta operación se usa un anestásico para dormir totalmente al niño. Este procedimiento permite que el niño vuelva a oír normalmente.

Hable con el médico sobre el costo y las posibles desventajas de este procedimiento.

Los tubitos permanecen en los oídos hasta que se caen solos, o hasta que el médico decide que ya no son necesarios. Uno de cada tres niños tendrá que someterse al mismo procedimiento en algún momento durante los 5 años después de la primera operación.

## ¿Cuáles son los beneficios y desventajas de los tratamientos?

La siguiente tabla indica los beneficios y posibles desventajas de los tratamientos disponibles para que hable sobre ellos con el médico.

[Tabla 1. Posibles beneficios y desventajas con el médico de su niño]

Tratamiento | Beneficios | Desventajas
Observación médica sin tratamiento | En el 60% de los casos, el líquido en el oído desaparece en un período de 3 meses, y en 85% de los casos no desaparecerá en 6 meses. El costo es bajo y no existen efectos secundarios molestos. | - En el 40% de los casos el líquido no desaparece en 3 meses, y en 15% de los casos no desaparecerá en 6 meses.
Tratamiento con antibióticos | - Aumenta en un 14% la posibilidad que desaparezca el líquido, y que desaparezca más rápidamente.; - Puede reducir la posibilidad que hayan infecciones del oído. | - Es posible que no desaparezca el líquido en el oído.; - Efectos molestos no deseados (como diarrea e irritaciones de la piel).; - Infecciones de bacterias más resistentes al medicamento. Esto puede hacer más difícil curar al niño.; - Tener que comprar y administrar los medicamentos.; - El costo del medicamento.
Cirugía (tubos) | - Se extrae el líquido del oído de inmediato.; - El niño vuelve a oír normalmente de inmediato. | - Las molestias temporales para el niño.; - Los riesgos de la anestesia.; - Probablemente se tienen que proteger los oídos durante los baños o al ir a nadar (mientras que los tubos permanecen colocados.); - Algunos niños necesitan otra cirugía para intoducir tubos nuevos.; - Es posible que hayan cambios en el tímpano.; - El tiempo necesario para llevar al niño a la operación y su cuidado.; - Es la más costosa de las alternativas de tratamiento.

## ¿Cuándo se debe dar tratamiento para esta condición?

El tratamiento que necesita su niño depende de:

- Por cuánto tiempo ha tenido el líquido en los oídos.
- Si la acumulación de líquido está causando problemas de sordera parcial.

Estos son algunos ejemplos de los posibles tratamientos para la acumulación de líquido en el oído medio. Recuerde que antes de decidir tiene que hablar sobre las alternativas y los posibles beneficios y desventajas con el médico de su niño.

Si el niño ha tenido la condición por tres meses, los expertos recomiendan los siguientes pasos:

- Observación médica o tratamiento con antibióticos. Es probable que recomienden la observación sin tratamiento, ya que los antibióticos pueden provocar efectos molestos.
- Tomar pasos para prevenir la condición (especialmente en el caso que su niño viva en un ambiente de fumadores).

Si el niño ha tenido la condición por 3 meses o más, los expertos recomiendan:

- Observación médica o tratamiento con antibióticos. Es probable que recomienden la observación sin tratamiento, ya que los antibióticos pueden provocar efectos molestos.
- Tomar pasos para prevenir la condición (especialmente en el caso que su niño viva en un ambiente de fumadores).

También

- Se recomienda un examen de audición para determinar si hay sordera parcial. Si este examen muestra sordera parcial en ambos oídos, el médico probablemente recomendará la cirugía para insertar los tubos en los timpaños.
- Hable con el médico si tiene otras preocupaciones en cuanto al desarrollo del niño, por ejemplo, si nota que el niño no empieza a hablar al mismo tiempo que otros de su edad.

Los expertos recomiendan lo siguiente en caso que el niño haya tenido líquido entre 4 a 6 meses con sordera parcial en ambos oídos:

- Cirugía para insertar tubos en los timpaños. Los tubos sirven para drenar (sacar) el líquido del oído y permitir que el niño vuelva a oír normalmente. Hable sobre la cirugía con el médico.

También

- Hable con el médico sobre cómo proteger los oídos del niño para que no penetre el agua durante el baño, y cuándo le debe volver a llevar al médico después de la operación.

## ¿Cuáles tratamientos no se recomiendan?

Existen varios tratamientos y operaciones que no se recomiendan en caso de que su niño tenga líquido en el oído medio. Los médicamentos que no se recomiendan son:

- Los descongestionantes o antihistamínicos (para los resfriados y/o las alergias).
- Esteroides.

La mayoría de los estudios científicos indican que el uso combinado o individual de estos medicamentos no mejora ni cura el líquido en el oído medio.

No existen suficientes estudios para evaluar la eficacia de los esteroides en el tratamiento de esta condición.

Las cirugías que no se recomiendan son:

- Adenoidectomía (extraer los adenoides).
- Amigdalectomía (extraer las amigdalas o anginas).

La adenoidectomía es una operación en la que se sacan los adenoides, que son tejidos en la parte posterior de la nariz. Todavía no existen suficientes estudios científicos que muestren que esta cirugía sea eficaz en niños menores de 4 años de edad. Para los niños mayores de esta edad, sí ha dado buenos resultados. La amigdalectomía es una operación en la que se extraen las amigdalas (anginas) que se encuentran en la parte posterior de la garganta. No se ha podido demostrar que esta operación ayuda a remediar los problemas causados por esta condición.

Si su médico recomienda una de estas dos operaciones, puede ser que exista algún otro problema de salud para el cual sean necesarias. Hable con él sobre la razón por la que recomienda la operación y, si tiene alguna duda, es mejor que busque la opinión de otro médico antes de aceptarla.

## ¿Cómo puedo seguir el historial de problemas del oído de mi niño?

La siguiente tabla le permitirá anotar los problemas del oído que sufra su niño y los tratamientos que se le proporcionen (puede pedir al médico o la enfermera que le ayuden a anotar la información correcta). Esto puede ayudar al médico a encontrar la causa del problema.

__________________________________________________________ De (nombre del niño) __________________________________________________________ Nombre del médico o enfermera a cargo de su cuidado __________________________________________________________ Teléfono

Fecha y tipo de problema (líquido en el oído medio o infección del oído) | Tratamiento | Resultados

## Para obtener más información

La información en esta publicación se obtuvo de la Clinical Practice Guideline, Otitis Media with Effusion in Young Children. La Guía fue desarrollada por un panel de expertos patrocinados por la Agency for Health Care Policy and Research (AHCPR), una agencia del Servicio de Salud Pública de los Estados Unidos. Existen y se están desarrollando otras Guías para pacientes en inglés y en español sobre diversos problemas de salud.

Para más información sobre las Guías para el paciente o para recibir más copias de esta publicación, llame gratis al 1-800-358-9295, o escriba a:

- AHCPR Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, Maryland 20907