# La insuficiencia cardíaca

## El corazón

El corazón es un órgano importante del cuerpo que se encarga de bombear continuamente la sangre que le proporciona al cuerpo nutrientes y oxígeno. Es del tamaño de un puño y un poderoso músculo que utiliza su propio sistema "eléctrico" para funcionar como una bomba y circular la sangre. Durante el descanso, el corazón irriga entre 5 a 6 litros ("quarts") de sangre al cuerpo cada minuto; pero esta cantidad de sangre puede aumentar hasta 20 litros por minuto cuando la persona está haciendo ejercicio o esfuerzo físico.

Normalmente el corazón responde automáticamente a las necesidades del cuerpo. Es decir, cuando el cuerpo necesita más nutrientes y oxígeno porque está haciendo esfuerzo físico (como subir escaleras), el corazón responde latiendo más rápido y más fuerte. Al latir más rápidamente, el corazón distribuye más sangre rica en nutrientes y oxígeno a todos los músculos y órganos del cuerpo. A su vez, la sangre que necesita más nutrientes y oxígeno, regresa al corazón para volver a circular a través del cuerpo.

Cuando una persona padece de insuficiencia cardíaca, su corazón se encuentra débil y tiene menor capacidad para bombear sangre. A pesar que puede continuar latiendo normalmente, el corazón no distribuye la misma cantidad de sangre con cada latido. Los síntomas de cada paciente varían de acuerdo a la severidad de la condición.

## El propósito de esta publicación

Esta publicación le ayudará si usted o alguien en su familia padece de insuficiencia cardíaca debido a que el corazón tiene menor capacidad de bombear sangre (disfunción ventricular sistólica izquierda). El aprender acerca de esta condición y seguir algunas recomendaciones sencillas pueden ayudar a mejorar la calidad de vida del paciente.

La publicación le ayudará al paciente y su familia a participar en su cuidado médico, trabajando en cooperación con el grupo de cuidado de salud (médicos, enfermeras y otros profesionales). Esta guía le ayudará a mejorar su vida a pesar de la condición; así que probablemente deseará compartirla con sus familiares y otras personas a cargo de su cuidado.

Leer esta publicación le ayudará a entender como y por que la insuficiencia cardíaca afecta a su cuerpo. También le dará información sobre como responder a los síntomas y lo que puede esperar de los tratamientos disponibles. El aprender sobre la condición y participar activamente en su atención médica le permitirá mejorar su calidad de vida.

## ¿Qué es la insuficiencia cardíaca?

La insuficiencia cardíaca quiere decir que su corazón tiene una menor capacidad para bombear sangre. A pesar que el corazón sigue latiendo, su menor capacidad para bombear sangre resulta en que el cuerpo recibe menos nutrientes y oxígeno de los que necesita. El paciente tendrá dificultad para caminar, cargar cosas o subir escaleras. Probablemente sentirá que le falta el aliento (aire); dado que el cuerpo no tiene suficiente oxígeno para funcionar normalmente.

Para la mayoría de los pacientes, la insuficiencia cardíaca es una condición crónica. Es decir que pueden recibir tratamiento para controlarla, pero no existe una curación. Si la condición es el resultado de otros problemas médicos como la obstrucción de las arterias coronarias, o problemas de las válvulas cardíacas, la cirugía del corazón puede ayudar al paciente.

### Las causas de la insuficiencia cardíaca

Las causas más comunes de la insuficiencia cardíaca son las siguientes:

- Enfermedades de las arterias coronarias, por lo general con un ataque cardíaco previo (infarto miocárdico).
- Defecto muscular cardíaco (cardiomiopatía).
- Alta presión sanguínea (hipertensión).
- Enfermedades de las válvulas cardíacas.

A veces no se puede identificar la causa de la insuficiencia cardíaca. Sin embargo, la causa de la condición no es tan importante como lo que se puede hacer para ayudarle en caso que su corazón tenga menor capacidad para bombear sangre.

### Síntomas

Marque (X) los síntomas que usted presente:

- [ ] Dificultad para respirar, especialmente cuando hace un esfuerzo físico, o cuando se encuentra descansando (acostado).
- [ ] Despertar del sueño y sentir que le falta el aliento (aire).
- [ ] Tos seca y frecuente, especialmente cuando se encuentra acostado.
- [ ] Sentirse cansado o débil.
- [ ] Mareos o desmayos.
- [ ] Hinchazón de los pies, los tobillos, y las piernas (edema).
- [ ] Náuseas, con inflamación abdominal, dolor, o dolor al contacto.

Existen otros problemas que pueden producir los mismos síntomas, así es que es necesario que se le realice un examen médico completo. Para diagnosticar e identificar la causa probable de la insuficiencia cardíaca, es necesario obtener un historial médico y ciertos exámenes de evaluación.

### Las causas de los síntomas

Cuando el corazón está sano, puede responder a las necesidades del cuerpo y aumentar el flujo de sangre oxigenada a los órganos vitales y los músculos.

Cuando el corazón no está sano y tiene menos capacidad y menos fuerza, no puede bombear suficiente sangre para responder a las necesidades de los músculos y órganos.

Por esto, su cuerpo no puede realizar las mismas actividades que antes. Otro síntoma es que se acumulan o retienen sangre y líquidos en los pulmones, causando problemas para respirar cuando el paciente se encuentra acostado. Los líquidos también se pueden acumular en otras partes del cuerpo causando hinchazón de los pies, los tobillos, las piernas o el abdomen (estómago).

### El funcionamiento de las cavidades y válvulas cardíacas

Aprender sobre el funcionamiento de su corazón le ayudará a entender su plan de tratamiento y le permitirá desempeñar un papel activo en las decisiones sobre éste.

Antes de circular al cuerpo, la sangre pasa por las cavidades cardíacas que incluyen dos aurículas y dos ventrículos. Como podrá ver en el dibujo 1, la sangre del cuerpo regresa al corazón a través de las venas y entra a la aurícula derecha (a). De ahí, la sangre baja al ventrículo derecho (b). Mientras tanto, la sangre oxigenada de los pulmones entra a la aurícula izquierda (c) en el otro lado del corazón. Entonces, la sangre pasa por una válvula para llegar al ventrículo izquierdo (d).

Dibujo 1. La sangre en el corazon

En el dibujo 2, puede ver el ventrículo derecho, éste se contrae después de recibir la sangre de la aurícula derecha y envía la sangre a los pulmones para que reciba oxígeno (a). Al mismo tiempo, el ventrículo izquierdo se contrae después de recibir sangre oxigenada y la envía al resto del cuerpo (b).

El corazón también tiene cuatro válvulas. Dos de ellas se encargan de impedir que la sangre retroceda entre las aurículas y los ventrículos. De la misma manera, las otras dos válvulas se encargan de evitar que el flujo sanguíneo retroceda de las arterias hacia los ventrículos.

Normalmente, en cada latido del corazón el ventrículo izquierdo se encarga de bombear más de la mitad de la sangre que irriga al cuerpo. Cuando existe insuficiencia cardíaca, el ventrículo izquierdo no se puede contraer con la suficiente fuerza y sólo puede bombear 40 por ciento de la sangre que debería impulsar con cada latido del corazón.

Dibujo 2. La sangre saliendo del corazon

## El grupo de cuidado médico

Debido a que la insuficiencia cardíaca es una condición complicada, es necesario que reciba atención de varios tipos de profesionales de la salud que cuentan con diferentes capacidades.

El cooperar con este grupo de cuidado para aprender más sobre su condición le permitirá vivir mejor y por más tiempo.

Los profesionales a cargo de su cuidado pueden incluir a:

- El médico de cabecera (internista "primary care doctor"). El médico que generalmente le da todo su cuidado de salud. Los internistas o médicos de familia son los encargados de proporcionar el cuidado básico de salud.
- Un cardiólogo, es un especialista en enfermedades del corazón a quien le enviará su médico de cabecera si así lo cree necesario.
- Otros médicos, como los cirujanos y otros especialistas que pueden participar en su cuidado si así lo creen necesario el médico de cabecera o el cardiólogo.
- Enfermeras clínicas y otras enfermeras, a cargo de su cuidado médico en diferentes momentos. Pueden ser una fuente de información y de educación en cuanto a su condición.
- Otros profesionales de la salud, incluyendo a asistentes médicos (profesionales capacitados para tratar ciertas enfermedades y condiciones sin ser médicos titulados), enfermeras, especialistas en dietética (alimentación), y en terapias física y ocupacional, farmacéuticos, especialistas en el manejo de cada caso ("case managers"), trabajadores sociales, y otros especialistas en salud mental.

Usted y su familia son parte importante del grupo de cuidado médico. Antes de visitar al médico o cualquier otro de los miembros de su grupo de atención de la salud, escriba todas sus preguntas. Si así lo desea, marque las partes que no entienda de esta publicación para que se las expliquen, y pídales cualquier otra información necesaria. Con la ayuda de la lista de preguntas que se presenta al final de esta publicación, converse con el médico o la enfermera sobre sus dudas y otros asuntos que considere importantes sobre su atención médica.

Participe en las decisiones de su tratamiento.

## El diagnóstico y la evaluación

La siguiente información es importante para su evaluación médica:

- ?Cuáles son sus síntomas y por cuánto tiempo los ha tenido?
- Si anteriormente usted ha tenido un ataque cardíaco, un soplo cardíaco ("murmur"), u otros problemas. Si este es el caso ¿cuáles tratamientos ha recibido para estos problemas?
- Sus antecedentes de salud y su estado general de salud. ¿Que otros problemas de salud tiene? ¿qué tratamientos está recibiendo para estos problemas? ¿tiene restricciones en su alimentación, actividades o programa de ejercicios? ¿existen otros miembros de su familia que tienen problemas del corazón?
- Los detalles sobre su estilo de vida, ¿cuáles son sus rutinas diarias? ¿Que hace para prevenir problemas de la salud?
- ¿Bebe alcohol (licor), fuma, o consume drogas ilegales?

Trate de ser honesto al proporcionar esta información a su médico o enfermera. Recuerde que esta información es confidencial y no se le dará a nadie más. La evaluación, tratamiento y control de la condición dependen de esta información. Existen ciertos detalles que sólo usted y sus familiares le pueden proporcionar al médico.

Una cuidadosa entrevista para obtener el historial médico de familia, una radiografía de pecho, un examen físico y un electrocardiograma también ayudarán a diagnosticar correctamente la insuficiencia cardíaca.

Además de la información obtenida de los síntomas específicos y los resultados de los exámenes de evaluación iniciales, también será necesario realizar otro examen que mide la cantidad de sangre que bombea el corazón con cada latido (conocido como examen de fracción de eyección). Cuando se cree que el paciente tiene insuficiencia cardíaca, también se realizará una ecocardiografía o una ventriculografía radionúclida para medir la fracción de eyección.

### Ecocardiografía.

Se usan ondas de sonido (sonograma) para producir imágenes de las cavidades cardíacas. El examen no tiene peligros y no es necesario introducir instrumentos al cuerpo.

### Ventriculografía radionúclida.

En este examen, se introduce una sustancia de contraste (tiente) radioactiva para obtener imágenes del corazón conforme ésta circula en las diversas cavidades cardíacas. La sustancia radioactiva no es peligrosa y se elimina completamente después del examen.

Como ya dijimos, con cada latido el corazón sano bombea el 50 por ciento o más de la sangre que se encuentra en el ventrículo izquierdo. Cuando existe insuficiencia cardíaca, el corazón debilitado sólo puede bombear el 40 por ciento, o menos, de la sangre al resto del cuerpo.

## El control de la insuficiencia cardíaca

Para controlar la insuficiencia cardíaca, el paciente tiene que seguir cuidadosamente las instrucciones y recomendaciones de su médico. Se pueden aliviar los síntomas y mejorar la calidad de vida con el uso de medicamentos y ciertos cambios en la rutina de vida.

Coopere con su médico y enfermera para tomar las decisiones más adecuadas en cuanto a su tratamiento y para definir ciertas metas que le puedan ayudar a mantener una vida plena.

El plan de control de su condición incluye:

- Medicamentos.
- Dieta.
- Actividades diarias.
- Ejercicio.
- Hábitos y estilo de vida.
- Apoyo de familiares.

Si usted no está de acuerdo con las recomendaciones de tratamiento o los medicamentos, tiene que hablar con el médico sobre sus razones y cooperar con él para encontrar alternativas.

Coopere con el médico para aprender a controlar su condición.

### Medicamentos

#### Su importancia

Tomar los medicamentos indicados es una parte importante del tratamiento de la insuficiencia cardíaca. Dependiendo de sus síntomas y diagnóstico, es probable que el médico inicie el tratamiento con un medicamento y que agregue otros con el tiempo. A veces, el tratamiento se iniciará con el uso de dos o más medicamentos.

Pueden pasar varios días o semanas antes de encontrar los medicamentos o dosis (cantidades) adecuados en su caso. Sea paciente y coopere con su médico para encontrar:

- Los medicamentos adecuados.
- Las dosis adecuadas de cada medicamento.
- La mejor hora del día para tomar cada medicamento.

Los beneficios de cada medicamento se perderán o serán menores si usted no los toma exactamente como lo indique el médico. No tomar una de las dosis, o no comprar más medicamentos cuando se acaben, puede resultar en problemas muy serios. También es importante que no tome mayores dosis de las que le indiquen.

Asegúrese de informar al médico sobre otros problemas de salud y los medicamentos que toma para éstos.

Informe al médico si toma medicamentos sin receta tales como la aspirina, los antiácidos y los medicamentos para el resfriado. También infórmele de otros remedios que tome; para asegurarse que no hay problemas con el uso combinado de éstos y sus nuevos medicamentos.

#### Efectos secundarios

Cualquier medicamento puede tener efectos no deseados. Si los medicamentos que toma para su condición le causan cualquier efecto secundario, es importante que se lo diga al médico o la enfermera de inmediato. Ellos le pueden ayudar a evitar o aliviar los efectos molestos. Si los medicamentos que le recetan inicialmente no son eficaces, existen otras alternativas.

Pregunte al médico o la enfermera sobre los efectos secundarios que pueden resultar de consumir sus medicamentos y:

- Tomar medicamentos recetados por un médico para otras enfermedades o problemas de salud.
- Tomar medicamentos que compra sin receta médica, tales como la aspirina, los antiácidos, los medicamentos para el resfriado y otros remedios.
- Comer ciertos alimentos.

Siempre informe de inmediato al médico o la enfermera sobre los efectos secundarios.

#### Los medicamentos comunes en el tratamiento de la condición

Los medicamentos más comunes en el tratamiento de la insuficiencia cardíaca incluyen los siguientes:

- Inhibidores de la enzima convertidora ("ACE inhibitors"). Se usan para permitir que el corazón lata con menor dificultad.
- Diuréticos. Se usan para desechar el exceso de líquidos y sales que se acumulan en el cuerpo.
- Digitales ("digitalis"). Se usan para fortalecer los latidos del corazón y permitir un mayor flujo de sangre.

Cuando existen otros problemas de salud o del corazón además de la insuficiencia cardíaca, es probable que su médico le recete otros medicamentos tales como aquéllos para controlar la alta presión sanguínea.

##### Inhibidores de la enzima convertidora ("ACE inhibitors")

Se ha comprobado que estos medicamentos permiten que los pacientes que padecen de insuficiencia cardíaca vivan mejor y por más tiempo. Los inhibidores relajan los vasos sanguíneos y ayudan a mejorar el latido del corazón. Algunos pacientes tienen que esperar varias semanas antes de sentir los beneficios.

Dependiendo de su diagnóstico y evaluación iniciales, es posible que estos medicamentos sean los primeros que se le receten. Dependiendo de sus síntomas, es posible que le receten diuréticos y digitales al mismo tiempo, o que se agreguen más tarde.

Los inhibidores de la enzima convertidora que se usan en el tratamiento de la insuficiencia cardíaca son el captopril, enalapril, lisinopril y quinapril. Probablemente en el futuro se usarán otros medicamentos de este tipo para la insuficiencia cardíaca.

La mayoría de los pacientes no sufren problemas cuando toman estos medicamentos. Cuando se presentan problemas, los más comunes incluyen:

- Tos.
- Mareo.
- Irritaciones de la piel.

Si presenta cualquiera de estos síntomas, repórtelo a su médico o enfermera.

Estos medicamentos también pueden producir altos niveles de potasio y afectar la función renal (de los riñones). Para vigilar estos problemas, es necesario realizar exámenes de la sangre.

Reporte los efectos secundarios de inmediato.

##### Diuréticos.

Al hacer que orine con más frecuencia, los diuréticos ayudan a eliminar los líquidos que se pueden acumular en los pies, tobillos, piernas o abdomen (estómago). El olvidar tomar una de las dosis de estos medicamentos puede causar hinchazón de estas partes del cuerpo o falta de aliento cuando se acueste o realice actividades físicas.

Los diuréticos de uso más común son la hidroclorotiazida y la furosemida (Lasix).

El uso prolongado de diuréticos puede resultar en que el cuerpo pierda potasio y causar otros problemas. Para vigilar los niveles de estas sustancias es necesario realizar análisis de sangre.

Para reemplazar el potasio en el cuerpo es probable que le recomienden:

- Comer más alimentos ricos en potasio, como los plátanos (guineos), las pasas, el jugo de naranja y otros cítricos.
- Tomar suplementos de potasio.

Los diuréticos también pueden causar:

- Calambres (contracciones) en las piernas.
- Mareos.
- Incontinencia urinaria (perder orina involuntariamente).
- Gota (un tipo de artritis).
- Irritaciones de la piel.

Hable con su médico o enfermera si presenta cualquiera de estos síntomas. El orinar más frecuentemente es el efecto deseado, así es que no tiene que reportarlo al médico.

##### Digitales.

Los digitales mejoran el latido del corazón y pueden ayudarle a realizar mayor esfuerzo físico y ejercicio. Muchos pacientes con condiciones cardíacas toman digitales diariamente, recetados bajo los nombres comerciales de Digoxina o Lanoxina.

Los digitales generalmente no son peligrosos, pero si un paciente tiene demasiado en su sangre, puede presentar:

- Náusea, pérdida del apetito.
- Confusión mental.
- Visión nublada o amarillenta.
- Latidos del corazón fuertes o acelerados (palpitaciones).

Hable con su médico inmediatamente si presenta cualquiera de estos efectos secundarios; pero no deje de tomarlos a menos que así lo indique el médico.

#### Vigilar el uso de sus medicamentos

Si toma varios medicamentos a diferentes horas del día, el mantener una lista de su uso puede ayudarle a seguir su tratamiento. Use la tabla al final de esta publicación para recordarle:

- Cuáles medicamentos tomar diariamente.
- La apariencia de cada pastilla o píldora que debe tomar.
- Cuándo tomar cada medicamento.
- Anotar los medicamentos que ya ha tomado.

Saque copias de la tabla para poder usarla muchas veces.

Siempre lleve consigo una lista de la dosis y los medicamentos que toma. En caso de emergencia, esta información puede ayudar mucho a los médicos a cargo de su cuidado.

Tabla semanal de uso de medicamentos

Nombre y dosis del medicamento | Tamano, forma y color del medicamento | Cuando tomarlo | Marqe con una "X" en el dia correspondiente, cada vez que tome el medicamento
Nombre y dosis del medicamento | Tamano, forma y color del medicamento | Cuando tomarlo | Dom | Lun | Mar | Mier | Jue | Vier | Sab
1. | --- | --- | --- | --- | --- | --- | --- | --- | ---
1. | --- | --- | --- | --- | --- | --- | --- | --- | ---
1. | --- | --- | --- | --- | --- | --- | --- | --- | ---
2. | --- | --- | --- | --- | --- | --- | --- | --- | ---
2. | --- | --- | --- | --- | --- | --- | --- | --- | ---
2. | --- | --- | --- | --- | --- | --- | --- | --- | ---
3. | --- | --- | --- | --- | --- | --- | --- | --- | ---
3. | --- | --- | --- | --- | --- | --- | --- | --- | ---
3. | --- | --- | --- | --- | --- | --- | --- | --- | ---
4. | --- | --- | --- | --- | --- | --- | --- | --- | ---
4. | --- | --- | --- | --- | --- | --- | --- | --- | ---
4. | --- | --- | --- | --- | --- | --- | --- | --- | ---

#### Costo de los medicamentos

El costo de los medicamentos varía significativamente de una farmacia a otra. Si el costo de sus medicamentos es demasiado para usted, pida a su médico o farmacéutico que le ayude a encontrar medicamentos de marca genérica adecuados y a menor costo. También puede comparar los precios entre farmacias e incluso ordenar sus medicamentos a través del correo.

Si es necesario, pude obtener ayuda financiera a través de las agencias de servicios sociales en su comunidad. Probablemente, también podría reunir los requisitos necesarios para obtener ayuda a través de los programas de las compañías farmacéuticas.

Hable con el médico o la enfermera si tiene problemas para cubrir el costo de sus medicamentos. Ellos le pueden ayudar a solicitar la ayuda necesaria.

### Dieta

Además de tomar medicamentos, deberá hacer cambios y vigilar su alimentación. Debido a que la sal (sodio) causa acumulación de líquidos en el cuerpo, deberá de reducir el consumo de esta. Si no lo hace, los líquidos se acumularán y causarán hinchazón en sus pies, tobillos, piernas y abdomen. También le pueden causar problemas para respirar. Si estos síntomas llegan a ser severos, es probable que necesite recibir atención médica en el hospital.

El médico le dirá cuál es la cantidad adecuada de sal que puede consumir, o si no puede consumirla. Probablemente le enviarán a consultar a un especialista en dietética (alimentación), una enfermera, u otro especialista que le dará las instrucciones necesarias en cuanto a su dieta. Probablemente le ayudarán a encontrar nuevas formas de cocinar los alimentos o a modificar las recetas de la familia. Por ejemplo, el uso del jugo de limón y otros condimentos y hierbas de olor puede reemplazar la sal en muchos alimentos.

Tiene que prestar especial atención a aquellos alimentos que tienen altos contenidos de sodio o sal, tales como las comidas de lata o congeladas, los quesos, y las carnes frías (embutidos). Ejemplos específicos de este tipo de alimentos son los embutidos como las salchichas y los chorizos, las sopas de lata y las papas y tortillas fritas. Lea las etiquetas de los ingredientes de los alimentos y busque el contenido de sal o sodio.

Si consume bebidas alcohólicas, es probable que tenga que dejar de hacerlo, o que sólo pueda tomar una ración al día. Una ración al día quiere decir un vaso de vino o cerveza, o sólo un trago de una bebida mixta con un contenido de alcohol no mayor de una onza.

Cambiar sus hábitos alimenticios puede ser complicado. La meta es reducir el contenido de sodio o sal y grasas en su alimentación, y al mismo tiempo tratar de mantener el mejor sabor. Si encuentra difícil cambiar su alimentación, hable con el médico o la especialista en dietética.

Vigile su peso. Para hacer esto debe comprar una váscula precisa y usarla al despertar después de orinar pero antes de desayunar o vestirse.

Si sube entre 3 y 5 libras (uno kilo y medio a cuatro kilos) desde su última visita al médico, repórtelo de inmediato. Este aumento de peso puede indicar que su cuerpo está reteniendo líquidos.

### Actividades diarias

La insuficiencia cardíaca afectará su vida diaria dependiendo de su severidad. La insuficiencia leve puede afectar poco su trabajo y sus actividades recreativas. La insuficiencia severa, por otra parte, puede hacer que el paciente tenga que cambiar actividades diarias que antes le eran sencillas. Hable con el médico y la enfermera sobre:

- Trabajo. ¿Puede seguir trabajando de tiempo completo o de medio tiempo?
- Actividades recreativas. ¿Puede seguir haciendo ejercicio, caminar, o practicar deportes?
- Pasatiempos. ¿Puede viajar, trabajar en su jardín, o realizar actividades voluntarias para su iglesia?
- Sexo. ¿Puede tener relaciones sexuales?

Hable sobre sus actividades diarias con sus familiares ya que ellos le pueden dar apoyo y ayuda. Esto es de especial importancia cuando sus actividades tienen que cambiar con el tiempo. Ciertas actividades (como el trabajo y las actividades recreativas) pueden hacerse más difíciles conforme pasa el tiempo; mientras que la dificultad de otras actividades no cambia.

Puede ser que tenga que cambiar su estilo de vida y sus hábitos para mantener la salud.

No tema hablar sobre aspectos privados de su vida. Es importante que el médico y la enfermera sepan lo más posible de su rutina diaria, para ayudarle a aliviar o reducir los síntomas y mejorar su calidad de vida.

Conforme aprenda más sobre su condición, probablemente encontrará nuevas satisfacciones y placeres en su vida. Los cambios a las rutinas de la vida diaria pueden ser positivos e interesantes. Al tener que reducir su carga de trabajo, probablemente encontrará nuevas actividades recreativas. Probablemente los pasatiempos se convertirán en una parte importante de su vida diaria. Las relaciones sexuales también pueden ser muy satisfactorias al explorar nuevas, y menos difíciles, formas de compartir el amor físico.

### Ejercicio

Realice ejercicio físico de acuerdo a las recomendaciones y limitaciones que le indique el médico. Muchos pacientes que padecen de insuficiencia cardíaca afirman que se sienten mejor cuando realizan ejercicio físico regularmente. Puede realizar ejercicio sin peligro en casa, en un centro de rehabilitación como el hospital, en un club de ejercicio, un centro recreativo, la YMCA, o la YWCA.

Los ejercicios físicos incluyen:

- Caminar.
- Andar en bicicleta.
- Nadar.
- Ejercicios aeróbicos de bajo impacto.

El médico le indicará el tipo y cantidad de ejercicio adecuado en su caso. Es importante consultarle antes de iniciar el programa de ejercicio. Probablemente le enviarán a visitar un especialista en rehabilitación cardíaca, quien le ayudará a diseñar un plan de ejercicio y a vigilar sus resultados y efectos. Probablemente también será necesario que le realicen un examen de tolerancia al esfuerzo ("stress test") para determinar los límites de ejercicio físico que puede realizar sin correr peligro.

### Estilo de vida y los hábitos para mantener la salud

Su estilo de vida es el resultado de sus valores y sus creencias. Los hábitos para mantener la salud son aquéllos que le ayudan a prevenir las probabilidades de padecer de enfermedades o de sufrir lesiones. Cuando una persona padece de insuficiencia cardíaca, probablemente tendrá que cambiar su estilo de vida y modificar sus hábitos para mantener la salud.

Los siguientes cambios le pueden ayudar a reducir los síntomas de la insuficiencia cardíaca y a mejorar su calidad de vida:

- Si pesa demasiado, tiene que reducir su peso.
- No fume o mastique tabaco.
- Elimine o reduzca su consumo de bebidas alcohólicas.
- No consuma drogas ilegales.

También:

- Evite realizar ejercicio que exceda las recomendaciones de su médico.
- Evite estar en contacto con personas que tienen resfriados.
- Vacúnese regularmente contra la pulmonía y la influenza ("flu").

Probablemente también le ayudará el hacer ciertos cambios como el reducir el nivel de tensión emocional. Hable con su médico y enfermera sobre estos y otros cambios que le pueden ayudar a mejorar su calidad de vida.

### Apoyo de su familia

Su familia puede ser una fuente de apoyo. En cuanto sea posible, incluyalos en todas las decisiones que afectarán su vida. Estas decisiones probablemente tendrán impacto en su estilo de vida y en su capacidad de trabajar y ganar dinero. El apoyo de la familia puede ser de especial importancia cuando se tienen que realizar cambios y el paciente enfrenta dificultades emocionales. Dígale a sus familiares como le pueden ayudar.

Le pueden ayudar:

- A administrar y vigilar el uso de los medicamentos.
- A preparar alimentos especiales.
- A realizar ejercicio.
- A obtener información útil en cuanto al tratamiento y control de la insuficiencia cardíaca (especialmente si usted no habla inglés).
- A participar en grupos de apoyo.

El diagnóstico de insuficiencia cardíaca tiene un fuerte impacto en el paciente y su familia. El apoyo de sus familiares es una parte importante para ayudar al paciente a realizar los cambios necesarios en su estilo de vida y modificar sus hábitos para mantener la salud.

## Angina (dolor) de pecho

demás de tener síntomas de insuficiencia cardíaca algunos pacientes también sienten dolor o angina de pecho. La angina de pecho causa dolor debido a obstrucciones o estrechamientos de las arterias coronarias. Cuando este es el caso, es probable que sea necesario realizar un examen médico conocido como angiografía cardíaca (se introduce un catéter o tubo hasta el corazón para observarlo).

Durante la angiografía se introduce una sustancia a través del catéter y se toman rayos-x que muestran el grado de obstrucción de las coronarias. Antes de someterse a este examen, hable con el médico o la enfermera sobre sus beneficios y posibles desventajas.

Los resultados de la angiografía ayudan al médico y otros especialistas a diseñar un plan de tratamiento que puede incluir una operación. Si el paciente no quiere someterse a la cirugía, la angiografía no es necesaria. Nuevamente, es importante que hable con el médico sobre las posibles alternativas de tratamiento disponibles, de acuerdo a los resultados de los exámenes de evaluación.

## Cirugía del corazón

Si el médico cree que su insuficiencia cardíaca es el resultado de algún problema con las válvulas o arterias del corazón, es probable que recomiende una cirugía. Antes de aceptar esta alternativa, tiene que considerar toda la información disponible y los posibles resultados. Debe hablar con el médico sobre los siguientes aspectos:

- Beneficios.
- Desventajas, incluyendo la posibilidad que no dé resultados.
- Otras alternativas, y los beneficios y desventajas de éstas.
- El costo total, y cuánto pagará su compañía de seguro de salud.

Antes de decidir someterse a la cirugía, busque una segunda opinión de otro médico. Por lo general, las compañías de seguro de la salud, exigen que el paciente tenga una segunda opinión médica antes de aceptar cubrir los costos de este procedimiento.

Si la cirugía del corazón es una opción adecuada en su caso, es importante que busque un cirujano y hospital con amplia experiencia en este tipo de cirugía. Pregunte en cuanto a sus índices de éxito al realizar estas cirugías y hable de los costos antes de elegir el hospital y al cirujano.

### Cirugía valvular cardíaca

Cuando existen problemas valvulares, puede ser necesario reparar o reemplazar una o varias válvulas del corazón. Este tipo de cirugía es bastante común y es eficaz en la mayoría de los casos.

### Cirugía de puente coronario ("Bypass") y angioplastia

La cirugía de puente coronario es una cirugía mayor. Durante esta operación se utilizan trozos (injertos) de otras venas o arterias del cuerpo para crear un "puente" de paso para que la sangre pueda irrigar al músculo del corazón. La cirugía corrige obstrucciones en las arterias que proveen de sangre al corazón que, como cualquier otro músculo, necesita oxígeno para funcionar y bombear sangre.

La angioplastia es una alternativa a la cirugía de puente coronario ("percutaneous transluminal coronary angioplasty"). Durante este procedimiento, se inserta un catéter (tubo delgado) a través de una arteria y hasta el corazón. Al llegar al área de la obstrucción, se infla un globo en la punta del catéter. El globo expande la arteria coronaria y, al retirarlo, permite una mejor circulación de la sangre.

La investigación científica reciente indica que la cirugía de puente coronario puede ayudar a los pacientes que han empeorado y tienen insuficiencia cardíaca y angina de pecho causada por enfermedades de las coronarias. Sin embargo, aún no se han comprobado los beneficios a largo plazo del uso de la angioplastia.

Después de someterse a la cirugía, el paciente tiene que seguir un cuidadoso programa para vigilar y controlar su condición cardíaca.

### Cirugía de transplante de corazón

Los transplantes de corazón sólo se consideran en los casos en los que la insuficiencia cardíaca es muy grave. Los transplantes de corazón sólo se realizan en centros especializados en este tipo de cirugía.

## Vigilar su progreso

Para controlar la insuficiencia cardíaca es necesaria una cuidadosa observación de los síntomas y los efectos de los tratamientos. Seguir las instrucciones del médico y otros especialistas también permite proveer el mejor cuidado. Reporte cualquier cambio en su condición a su médico o enfermera.

### Las responsabilidades del paciente

Como un miembro del grupo a cargo de su atención médica, tiene que hacer lo siguiente:

- Vigilar su estado de salud en general y reportar al médico cualquier cambio.
- Reportar cualquier cambio en sus síntomas.
- Tomar los medicamentos siguiendo las indicaciones, y reportar cualquier efecto secundario.
- Seguir las recomendaciones de los especialistas en ejercicio y reportar cuando tenga dificultad para hacer cualquier actividad o ejercicio.
- Seguir las recomendaciones en cuanto a su alimentación (dieta).
- Reportar al médico cuando tenga cambios súbitos de peso.

### Las responsabilidades de la familia

La familia puede ayudar al paciente a seguir las recomendaciones para controlar y vigilar su condición. Ellos también deben saber y ayudarle a reportar al médico los cambios en los síntomas o cuando se presentan nuevos síntomas. Esto es especialmente importante si usted no habla inglés y alguien en su familia lo ayuda en sus conversaciones con los médicos y las enfermeras.

Al llamar al médico u otro especialista, sus familiares deben:

- Indicar que está recibiendo tratamiento para la insuficiencia cardíaca.
- Describir sus síntomas.
- Describir lo que ya se ha hecho para brindarle alivio.
- Dar los nombres y las dosis de los medicamentos que está tomando.

## El futuro

Hable con su médico de cabecera sobre la manera en la que la insuficiencia cardíaca afectará su vida. Muchos pacientes aprenden a disfrutar de la vida a pesar de las limitaciones que impone el padecer de esta condición.

A pesar que no es común que el paciente presente cambios súbitos en sus síntomas, existen ciertas actividades que ya no podrá realizar debido a que se cansa o le falta el aliento (aire). Si nota un cambio súbito en sus síntomas, es importante que lo reporte al médico de inmediato.

### Emergencias

En caso que se presente una emergencia médica, tal como que deje de respirar o que haya un paro del corazón, se asume que el paciente acepta el tratamiento médico. En los Estados Unidos existen ciertas alternativas legales en cuanto al tratamiento médico. Estas decisiones son derechos de cada individuo. Si usted siente que necesita ayuda para tomarlas, puede hablar con un familiar, un sacerdote, un miembro del clero o un consejero. Recuerde, esta es una decisión solamente suya, lo puede hacer o no hacer. Usted tiene el derecho de rehusar o aceptar los tratamientos médicos antes de que estos sean necesarios debido a una emergencia. Puede aclarar en un documento legal que usted no quiere que los técnicos de emergencia traten de volver a hacer que lata el corazón o que le coloquen una máquina especial que restaure la respiración.

Puede ser necesario que dé instrucciones específicas a sus familiares y otras personas para que sepan por adelantado cuáles son sus deseos en el caso de una emergencia. En los Estados Unidos existe un documento legal conocido como "instrucciones de cuidado médico" ("advance directive") que especifica sus deseos en caso de una emergencia. El documento especifica las medidas y tratamientos que usted aprueba y no aprueba en caso que durante la emergencia usted no pueda pensar o hablar claramente.

Las instrucciones de cuidado médico incluyen varios documentos:

- "Testamento en vida" ("living will"); que especifica sus deseos en caso de una emergencia médica, incapacitación severa, o enfermedad crónica.
- Agente de poder en caso de emergencia médica ("medical durable power of attorney"); que da poder legal a un pariente o amigo para ejecutar y autorizar sus deseos en caso de emergencia médica.
- Instrucciones para negar el uso de resurrección cardiopulmonar ("no cardiopulmonary resucitation").
- Agente de poder de decisiones médicas (medical proxies); un familiar o amigo a cargo de ejecutar y autorizar sus deseos en cuanto a su cuidado médico.

Antes de preparar este tipo de documento, si usted decide que lo quiere hacer, debe hablar con sus familiares y profesionales a cargo de su cuidado médico. Estas son decisiones serias y su grupo de cuidado médico le podrá ayudar a entender las consecuencias de estas decisiones. Hable con ellos y sus abogados en cuanto a estos documentos y las variaciones que existen de acuerdo a las leyes de su estado o comunidad (en los Estados Unidos).

### Grupos de apoyo y consejería

El diagnóstico de una enfermedad crónica como la insuficiencia cardíaca tiene un efecto emocional tanto en el paciente como en su familia. Es importante que discuta estas reacciones con su médico y otros profesionales a cargo de su cuidado de salud. Si es necesario, debe buscar ayuda para poder controlar estas emociones.

Además de los servicios profesionales de consejería, los grupos de apoyo en su localidad pueden ser de ayuda. El hablar en reuniones regulares con las familias y pacientes que tienen esta condición le será útil. Los grupos de apoyo probablemente también ofrecen programas educativos sobre las condiciones cardíacas.

Hable con su médico o enfermera sobre los grupos de apoyo, los servicios disponibles en español y otras fuentes de ayuda. Con la ayuda de su médico o enfermera, usted mismo puede iniciar un grupo de apoyo.

Muchos pacientes cambian su estilo de vida y aún tienen vidas activas y plenas.

Para obtener más información, consulte a:

- The Mended Hearts, Inc.
- 7272 Greenville Avenue
- Dallas, TX 75231
- (214) 706-1442

- The Coronary Club, Inc.
- 9500 Euclid Avenue, E-37
- Cleveland, OH 44195
- (216) 444-3690

Recuerde preguntar si cuentan con servicios en español.

## Cómo usar la tabla para anotar el uso de medicamentos

Use la siguiente tabla para anotar y vigilar el uso de medicamentos. Anote los medicamentos que toma cada día, la hora a la que los toma, y cuándo los ha tomado.

En la parte superior de la hoja, escriba su nombre y la fecha, empezando con el domingo.

Cada línea numerada es para un medicamento. En la primera columna, escriba el nombre y la dosis (cantidad) de cada medicamento. Por ejemplo: Lanoxin .25 mg. Puede encontrar el nombre y dosis del medicamento en la etiqueta del frasco que le dan en la farmacia.

En la segunda columna, escriba el tamaño, forma y color de la pastilla (píldora). Por ejemplo: Pequeña, redonda, y color blanco.

En la tercera columna, escriba cuándo se debe tomar el medicamento. Por ejemplo: Antes de desayunar.

Cuando ya ha tomado el medicamento, marque una x en la columna que corresponde al día de la semana. Si toma un medicamento varias veces al día, marque cada vez que lo haya tomado.

Haga copias de esta tabla para que la pueda usar cada semana.

## Otras fuentes de asistencia

Si usted o su familia desean obtener más información sobre la insuficiencia cardíaca y sus tratamientos, pueden acudir a la biblioteca pública y la librería en donde podrá obtener libros y artículos sobre esta condición. Los médicos y hospitales probablemente también le podrán proporcionar publicaciones, folletos, videos y audio cassettes con información sobre la insuficiencia cardíaca. También puede solicitar información de:

- The American Heart Association
- 7272 Greenville Avenue
- Dallas, TX 75231-4596
- Llame gratis al (800) 242-8721
- National Heart, Lung, and Blood Institute Information Center
- Public Health Service
- P.O. Box 30105
- Bethesda, MD 20824
- (301) 251-1222

Pregunte si tienen información en español.

## Para obtener más información

La información en esta publicación se obtuvo de la Heart Failure: Evaluation and Care of Patients With Left-Ventricular Systolic Dysfunction. Clinical Practice Guideline. La guía fue desarrollada por un panel de expertos patrocinados por la Agency for Health Care Policy and Research (AHCPR), una agencia del Servicio de Salud Pública de los Estados Unidos. Existen y se están desarrollando otras guías para pacientes en inglés y en español sobre diversos problemas de salud.

Para más información sobre las guías para el paciente o para recibir más copias de esta publicación, llame gratis al (800) 358-9295, o escriba a:

- AHCPR Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907
- U.S. Department of Health and Human Services Public Health Service
- Agency for Health Care Policy and Research
- Executive Office Center, Suite 501
- 2101 East Jefferson Street
- Rockville, MD 20852
- AHCPR Publication No. 94-0615
- Junio de 1994