# La angina de pecho inestable

## ¿Qué es la angina de pecho inestable?

La angina de pecho inestable es una forma de enfermedad de las arterias coronarias. El corazón es un músculo que se encarga de irrigar la sangre a todo el cuerpo. Como cualquier otro músculo, el corazón necesita oxígeno para funcionar adecuadamente y las coronarias son las que le llevan sangre rica en oxígeno. Cuando una persona padece de enfermedad de las coronarias, una o varias de estas arterias se encuentran parcial o totalmente obstruidas.

Imagen externa del corazón, mostrando las arterias coronarias

Normalmente, el tipo de enfermedad de las coronarias que padece cada paciente depende del grado de obstrucción de las coronarias. Un ataque cardíaco, conocido también como infarto miocárdico, sucede cuando el músculo del corazón ha sufrido daño debido a la falta de sangre oxigenada. La angina estable normalmente no deteriora al corazón. En cambio, le angina de pecho inestable es más grave, así es que si no se da tratamiento adecuado, puede resultar en un ataque cardíaco.

La falta de oxígeno al músculo del corazón causa la angina de pecho. Sus síntomas incluyen dolor o molestias en el pecho, los brazos, la espalda, el cuello, o la mandíbula. Algunas veces el dolor de angina se manifiesta como una sensación de opresión o presión en el tórax, o puede ser un dolor punzante o un adormecimiento (falta de sensación). Algunas personas confunden el dolor de angina con molestias de indigestión o gases.

El padecer de angina de pecho estable o inestable no necesariamente quiere decir que tendrá un ataque cardíaco. Sin embargo, la angina de pecho inestable es una condición grave para la cual necesitará recibir atención médica.

## El propósito de esta publicación

Esta publicación describe lo que es la angina de pecho y cómo se relaciona con otras enfermedades cardíacas. Responde a las preguntas más comunes sobre esta condición y describe los principales tratamientos.

La publicación es para las personas que padecen de angina de pecho, que han recibido tratamiento para enfermedades cardíacas, o que creen padecer de una enfermedad del corazón. También está dirigida a las personas que tienen un familiar o amigo que padece de angina estable o inestable.

Finalmente, se sugieren algunas preguntas que podrían ayudarle en sus conversaciones con el médico, y el momento oportuno para presentarlas.

## ¿ Cuál es la diferencia entre la angina de pecho estable e inestable?

Las molestias de la angina de pecho varían de un paciente a otro. Para algunos pacientes las molestias se presentan cuando realizan un esfuerzo físico (como cavar, o subir muchas escaleras). Otras personas sienten el dolor cuando se irritan o enfadan. Con el tiempo, los pacientes pueden predecir las situaciones o actividades que probablemente les van a provocar molestias. Normalmente estas molestias desaparecen en unos pocos minutos y se conocen como angina de pecho estable.

Los ataques de angina de pecho estable siguen un patrón (ritmo) regular. Sin embargo, para algunos pacientes estos patrones cambian y entonces la condición se conoce como angina de pecho inestable.

Los pacientes con angina de pecho inestable son aquéllos que:

- Sienten molestias de angina de pecho cuando se encuentran descansando, o las molestias los despiertan del sueño.
- Sin haber presentado síntoma alguno de angina de pecho, de momento tienen dolor entre moderado a severo y se sienten muy cansados (fatigados).
- Tienen un marcado aumento en la frecuencia o la intensidad de las molestias.

La angina de pecho inestable es una condición más grave que la angina de pecho estable, y el riesgo de que el paciente tenga un ataque al corazón es mayor.

## ¿ Qué provoca la angina de pecho inestable?

El paciente padece de una enfermedad de las coronarias cuando las paredes de estas arterias se obstruyen (estrechan) con depósitos de grasas u otras sustancias tales como el colesterol. Estas obstrucciones no son tan severas entre las personas que padecen de angina de pecho estable, así es que no alteran el flujo sanguíneo.

En los pacientes con angina de pecho inestable, estas obstrucciones llegan a ser tan grandes que tapan la arteria casi totalmente. Algunas veces la obstrucción se rompe y el cuerpo intenta cicatrizar (reparar) esta fisura produciendo un coágulo alrededor de la zona dañada. Cuando el coágulo es lo suficientemente grande para tapar el orificio de la arteria totalmente, puede interrumpir el flujo de sangre y causar un ataque cardíaco.

Imagen de un corte de una arteria coronaria mostrando segmentos normales y obstruidos (bloqueados)

## ¿ Necesito visitar al médico?

Esto depende de si su médico le ha dicho alguna vez que padece de una enfermedad de las coronarias.

Si siente dolor como el que se describe en la página 5 ("La angina de pecho puede ser una emergencia médica"), debe llamar una ambulancia de inmediato y después llamar a su médico.

### Las personas que no tienen antecedentes de enfermedad de las coronarias

La angina de pecho inestable frecuentemente se presenta entre personas que no sabían que tenían enfermedad de las coronarias. Cualquier dolor de pecho severo o nuevo que no se pueda explicar como el resultado de un accidente o golpe (tal como un músculo lesionado) podría ser angina de pecho inestable o un ataque cardíaco.

La angina de pecho no es una condición grave para las personas que reciben atención médica inmediata; pero puede ser muy seria si no se presta cuidado médico. Incluso el dolor de angina que desaparece cuando el paciente descansa puede ser serio. Solamente el médico puede decidir si sus molestias son el resultado de una condición seria y lo que se debe hacer al respecto.

### Las personas que tienen antecedentes de enfermedad de las coronarias

Para los pacientes con antecedentes de enfermedad de las coronarias, los síntomas en el pasado son la mejor manera de juzgar si es necesario llamar al médico al presentar nuevos síntomas. Llámelo si las molestias son más severas o duran más tiempo que antes; si las molestias ocurren con mayor frecuencia o con menor esfuerzo físico; o si siente molestias cuando está descansando o durmiendo.

### La angina de pecho puede ser una emergencia médica

Presentar cualquiera de los siguientes síntomas quiere decir que su angina de pecho es muy grave y que debe ir al hospital de inmediato:

- Dolor o molestias muy severos, que empeoran, y que duran por más de 20 minutos.
- Dolor o molestias acompañados por una sensación de malestar del estómago, o desmayo.
- Dolor o molestias que no desaparecen incluso después de tomar tres tabletas de nitroglicerina (vea las páginas 12 y 13).
- Dolor o molestias peores que los que ha tenido en el pasado.

Si vive en un área en donde no existe un servicio de ambulancia de emergencia, haga que alguien le lleve al hospital. Si se siente enfermo, no trate de guiar un automóvil para llegar al hospital.

También es importante hablar con familiares y amigos sobre su condición del corazón y dejar que lean esta publicación. Así ellos podrán reconocer los síntomas serios que indican la necesidad de ir al hospital. También dígales cuáles medicamentos tiene que tomar y el lugar en donde pueden encontrarlos en caso necesario.

## ¿ Qué sucederá en la sala de emergencias del hospital?

En la sala de emergencias del hospital, el médico determinará si usted tiene un ataque de angina de pecho. Si este es el caso, le darán medicamentos a través de la vena del brazo (intravenosos) para aliviar el dolor y prevenir que haya daño al corazón. Estos medicamentos ayudarán a prevenir coágulos de sangre, permitiendo que su corazón pueda latir con menor esfuerzo. Probablemente también le darán a respirar oxígeno para mejorar la oxigenación de su sangre.

Frecuentemente, los médicos y las enfermeras le preguntarán cómo se siente y si los medicamentos han aliviado el dolor y las molestias. Es importante que les diga exactamente cómo se siente, ya que si los medicamentos no alivian las molestias, hay otras alternativas para ayudarlo a sentirse mejor.

Las acciones en la sala de emergencias se tienen que realizar rápidamente y puede ser que los médicos y las enfermeras no tengan tiempo de explicarle lo que está sucediendo paso por paso. Habrá más tiempo para hablar y hacer todas sus preguntas una vez que el médico determine la seriedad de su condición.

### ¿ Qué es un electrocardiograma?

En la sala de emergencias le harán un electrocardiograma (conocido también como "ECG"). El electrocardiograma muestra la actividad eléctrica del latido de su corazón. Esta información mostrará si el músculo del corazón está recibiendo suficiente sangre oxigenada.

### ¿ Me tendré que quedar en el hospital?

Sus antecedentes (historial) médico, el electrocardiograma y el tipo de molestias que presente le indicarán al médico la seriedad de su condición.

Si el médico considera que su condición no es lo suficientemente seria para internarlo en el hospital, le dará una cita para verlo de nuevo y para realizar más exámenes médicos. Si las molestias en su pecho se vuelven a presentar antes de esa cita (o son como se describe en la sección "La angina de pecho puede ser una emergencia médica" página 5) debe regresar inmediatamente al hospital.

Diagnosticar la angina de pecho no es sencillo y es posible que el médico le tenga que ver varias veces para asegurarse del diagnóstico.

Si el médico decide internarlo en el hospital, puede ser que le den una cama en una sala regular o en la sala de cuidado intensivo. De cualquier manera, el tratamiento continuará mientras que se realizan más exámenes o estudios de evaluación.

Los exámenes médicos dependerán de la seriedad de su condición y la eficacia de los medicamentos en el control de sus molestias de angina de pecho.

## ¿Cuáles exámenes médicos realizarán?

Existe más de un examen de evaluación que se necesitará para determinar la seriedad de la obstrucción de sus coronarias. Algunos de estos exámenes se realizan mientras que está internado en el hospital. Otros exámenes se pueden realizar en el hospital, pero no tiene que pasar la noche ahí. Finalmente, algunos de los exámenes se pueden realizar en el consultorio del médico.

### Exámenes de tolerancia al esfuerzo ("stress tests")

Probablemente realizarán un examen de tolerancia al esfuerzo. En este examen, lo conectarán a una máquina de electrocardiograma mientras que realiza ejercicio en una bicicleta fija o en una banda deslizante. Puede ser que el médico también le inyecte una sustancia contrastante (tinte) radioactiva que permita ver sus vasos sanguíneos con unas cámaras especiales. El examen proporciona imágenes de los movimientos del músculo de su corazón y la manera en la que fluye la sangre.

El examen permite observar las alteraciones que suceden en el corazón mientras que su cuerpo realiza ejercicio. Durante el examen, el personal médico especializado vigilará su condición preguntándole cómo se siente. Asegúrese de seguir sus instrucciones cuidadosamente y decirles exactamente cómo se siente. (Si usted no habla inglés y no hay un médico o enfermera que hable español mientras realizan el examen, asegúrese que un familiar o amigo que hable ambos idiomas le acompañe.)

Si usted padece de otros problemas de la salud que impidan que realice ejercicio, le harán otro tipo de examen de tolerancia. Para realizar este examen, se le da un medicamento especial que hace que su corazón lata más rápidamente y que abre las arterias coronarias. El electrocardiograma que se toma durante este tipo de examen proporciona la misma información que se obtendría con el otro examen.

Los exámenes de tolerancia al esfuerzo con o sin ejercicio permiten determinar qué tan bien funciona su corazón. A pesar de que estos exámenes son útiles, el médico no puede obtener información precisa en cuanto al lugar o el grado de obstrucción de las coronarias. El grado de precisión de estos exámenes es de 90 por ciento. Por esta razón, es posible que también sea necesario realizar un cateterismo (angiograma) cardíaco.

### Cateterismo cardíaco

El angiograma (coronariografía) o cateterismo cardíaco permite que el médico observe las arterias coronarias directamente. Se introduce un tubo delgado conocido como catéter a través de una arteria en el brazo o la pierna. Viendo a través de una pantalla, el médico pasa el tubo por las arterias hasta llegar al corazón.

Con el catéter se mide la presión y circulación de la sangre en las arterias del corazón. Después se inyecta un líquido a través del catéter para tomar radiografías. Estas radiografías permiten ver el grado y ubicación de las obstrucciones de las coronarias.

El angiograma es un examen de evaluación no un tratamiento para la angina de pecho. El tratamiento para la angina de pecho que es parecido al angiograma se conoce como angioplastia y se describe en las páginas 14, 15 y 16.

## ¿ Qué muestran estos exámenes?

Los exámenes de tolerancia al esfuerzo muestran el grado de peligro que existe al corazón como resultado de las obstrucciones de las coronarias. El angiograma muestra la severidad y ubicación de las obstrucciones. El médico le informará que tiene enfermedad en una, dos o tres de las coronarias principales y el porcentaje de la obstrucción.

El número y porcentaje de la obstrucción de las coronarias se usan para medir la gravedad de su enfermedad. Por lo general, el mayor número de obstrucciones en las coronarias y la mayor deficiencia en la función cardíaca, indican una enfermedad más severa.

Estos exámenes dan mucha información sobre su condición. Es entonces que el médico le podrá dar más información en cuanto a la gravedad de su enfermedad y en cuanto a los tratamientos disponibles en su caso.

## Tratamientos para la angina de pecho inestable

Usted y el médico pueden decidir el tratamiento más adecuado en su caso. Las recomendaciones de tratamiento dependen de los resultados de sus exámenes médicos, si sigue teniendo molestias, y de sus propias preferencias. Por lo general, los tres principales tipos de tratamiento disponibles son: La terapia con medicamentos, la angioplastia, o la cirugía de puente coronario ("bypass").

### La terapia con medicamentos

Probablemente le dieron medicamentos durante su estadía en el hospital o la sala de emergencias. Algunos de estos medicamentos sólo se administran en el hospital; como el medicamento que se usa para evitar coágulos sanguíneos (heparina).

Muchos otros medicamentos que se usan en el tratamiento de la angina de pecho inestable se pueden tomar en casa. Estos incluyen pastillas (tabletas) o cremas que usted mismo puede administrar.

El sólo uso de medicamentos logra controlar la condición en muchos pacientes. Recuerde, que si los medicamentos no le brindan el alivio necesario, la angioplastia y la cirugía de puente coronario siempre siguen siendo opciones futuras.

Casi todos los pacientes de angina de pecho inestable recibirán algún tipo de medicamento. El médico o la enfermera le explicará exactamente cómo y cuándo tomarlos.

Existen varios tipos de medicamentos que se usan para aliviar las molestias de la angina de pecho inestable. Muchos de ellos también ayudan a reducir el esfuerzo del corazón para bombear sangre. Los medicamentos se pueden usar como tratamiento único o en combinación con los otros tratamientos que se describen más tarde.

El uso de medicamentos como tratamiento único probablemente es la opción adecuada para los pacientes que tienen otras enfermedades, o para los pacientes que no quieren someterse a la cirugía u otros tratamientos.

El uso de medicamentos como tratamiento único ayuda a los pacientes que:

- Tienen una o varias obstrucciones pero sólo en una de las coronarias;
- tienen obstrucciones menos severas;
- no padecen molestias severas de angina de pecho;
- se han estabilizado durante su estadía en el hospital.

Probablemente deseará hacer las siguientes preguntas sobre el tratamiento a su médico:

- ¿ Cuáles son los efectos secundarios (molestias) que tendré como resultado del uso de los medicamentos?
- ¿ Tendré que tomar medicamentos toda mi vida?

Algunos pacientes presentan efectos secundarios molestos provocados por los medicamentos, pero la mayoría de ellos notan mejoría de sus síntomas de angina de pecho. Si tiene una reacción negativa a los medicamentos, asegúrese de llamar al médico. Frecuentemente, la reacción negativa desaparece o disminuye con el tiempo; o se pueden hacer cambios en el uso de los medicamentos que permitirán ayudarle a sentirse mejor.

Recuerde, ninguno de los medicamentos elimina las obstrucciones en sus coronarias. Estos solamente disminuyen las molestias de la angina de pecho porque permiten que su corazón tenga mejor irrigación de sangre o que funcione con menos dificultad. Algunos de los medicamentos de uso común en el tratamiento de la angina de pecho inestable incluyen la aspirina, los nitratos y los betabloqueantes.

#### Aspirina

##### Cómo funciona

La mayoría de las personas piensan en la aspirina como un medicamento para aliviar los dolores de cabeza o la fiebre. Pero la aspirina también evita la formación de coágulos sanguíneos y estos coágulos son los que pueden obstruir las coronarias y causar un ataque cardíaco.

La investigación científica de los pacientes con angina de pecho inestable demuestra que una aspirina al día reduce el riesgo de ataques cardíacos y muerte. El Tylenol[TM] (acetaminofén), El Advil[TM] (ibuprofén) no son lo mismo que la aspirina y, en el caso de la angina de pecho, no se deben usar en lugar de ésta.

##### Efectos secundarios

A la mayoría de los pacientes con angina de pecho inestable se les recomendará el uso diario de aspirina. Cuando se usa la aspirina recubierta se presentan menos efectos secundarios. Se debe evitar el uso de aspirina si usted es alérgico a ella o si ha tenido úlceras u otros problemas de sangrados (hemorragias).

#### Nitratos

##### Cómo funcionan

Los nitratos (por lo general la nitroglicerina o el isosorbide) se usan para abrir las coronarias. Hacen menos difícil el funcionamiento del músculo del corazón y las coronarias porque aumentan la irrigación sanguínea. Los nitratos pueden aliviar las molestias de angina de pecho muy rápidamente.

Los nitratos vienen en varias formas de administración: Hay algunos que son unas pastillas (tabletas) que se colocan debajo de la lengua, otras tabletas que se tragan, parches que se colocan en la piel, o cremas que también se untan en la piel. Las pastillas, las cremas y los parches tienen uso por un tiempo limitado y, después de este período ya no funcionan. Es importante que hable con el farmacéutico acerca de las fechas límite de uso de estos medicamentos y cuándo se deben reemplazar por nuevos. Las cremas y parches de nitrato únicamente se usan como terapia de mantenimiento. Si los usa, también tendrá que tomar las pastillas para aliviar las molestias de la angina de pecho.

Tome una pastilla de nitroglicerina en cuanto sienta las molestias. Si las molestias no desaparecen en 5 minutos, tome otra pastilla. Si las molestias no desaparecen en otros 5 minutos, tome una tercera pastilla.

Si las molestias no han desaparecido después de tomar tres pastillas en un período de 20 minutos, vaya al hospital de inmediato. ¡Vaya de inmediato!

Las molestias persistentes (que no desaparecen) pueden ser señales que está sufriendo un ataque cardíaco y tiene que recibir atención médica inmediata.

##### Efectos secundarios

Probablemente sentirá mareo inmediatamente después de tomar los nitratos, así es que por lo general le dirán que los tome mientras se encuentra sentado. A algunos pacientes les dan dolores de cabeza.

#### Betabloqueantes

##### Cómo funcionan

Estos medicamentos disminuyen el esfuerzo y la cantidad de oxígeno que necesita el corazón para funcionar.

##### Efectos secundarios

Estos medicamentos son fuertes y pueden provocar muchos efectos secundarios. Aproximadamente el 10 por ciento de los pacientes que toman betabloqueantes se sienten cansados o mareados. El 5 por ciento de los pacientes pueden presentar depresión emocional, diarrea, o irritaciones de la piel. La confusión mental, los dolores de cabeza, agruras (acidez estomacal) o dolor de estómago y la falta de aliento (aire) son efectos secundarios mucho menos comunes.

### La angioplastia

Este procedimiento es similar al angiograma. Se introduce un catéter (tubo delgado) en una arteria de la ingle y se dirige directamente hacia la coronaria con la obstrucción. El catéter tiene un pequeño globo (balón) en la punta. Cuando el catéter llega al área de la obstrucción, el médico infla el globo lo suficiente para abrir el estrechamiento de la coronaria y permitir el flujo libre de la sangre, deteniendo así las molestias de la angina de pecho.

Las preguntas sobre la angioplastia que probablemente deseará hacer al médico:

- ¿ Necesitaré más angioplastias o cirugías de puente coronario en el futuro?
- ¿ Qué se siente al tener una angioplastia?
- ¿ Cuál es la probabilidad de que muera durante la angioplastia, y cuál es la probabilidad de tener otros problemas?

Imagen longitudinal de una arteria coronaria mostrando la manera en la que la angioplastia abre la obstrucción.

### Beneficios y desventajas de la angioplastia

Posibles beneficios:

- Aliviar el dolor causado por la angina de pecho.
- Poder aumentar el nivel de actividad o ejercicio del paciente.
- Permitir que el paciente realice actividades que había tenido que suspender debido a la condición.
- Reducir las cantidades de medicamento necesarias.
- Reducir el nivel de ansiedad/temor.

Posibles desventajas:

- Empeorar la angina de pecho.
- Necesidad de realizar una cirugía de puente coronario ("bypass") de emergencia.
- Ataque cardíaco.
- Daño a la coronaria.
- Que la coronaria se vuelva a obstruir (bloquear).
- Muerte.

### Cirugía de puente coronario ("bypass")

La cirugía se recomienda cuando el paciente tiene: Obstrucción severa en la coronaria principal izquierda o enfermedad en varias de las coronarias. La cirugía también es una opción cuando los medicamentos no controlan las molestias provocadas por la angina de pecho.

La cirugía de puente coronario puede ser muy eficaz en aumentar la cantidad de sangre que recibe el corazón y en aliviar las molestias de la angina de pecho. Como puede ver en la siguiente ilustración, en la cirugía se corta un segmento (injerto) de vena de la pierna o de una arteria del pecho, para crear un puente (bypass) que permita el paso a través del área de la coronaria que tiene la obstrucción más severa. Uno de los extremos del segmento se liga a la aorta, que es la arteria por donde pasa toda la sangre desde su corazón al resto del cuerpo. El otro extremo del segmento se liga con la coronaria por debajo de donde está la sección obstruida para así crear un puente de paso para la irrigación de la sangre.

Estas son algunas preguntas sobre la cirugía de puente coronario que le deseará hacer al médico:

- ¿ Cómo se siente el tener una cirugía de puente coronario?
- ¿ Es normal sentir temor de someterse a esta cirugía?
- ¿ Cuál es la probabilidad de que muera durante la cirugía, y cuál es la probabilidad de tener otros problemas?
- ¿ Necesitaré más cirugías en el futuro?

Imagen exterior del corazón que muestra los "puentes" coronarios para reparar las obstrucción de las arterias del corazón

### Beneficios y desventajas de la cirugía de puente (bypass) coronario

Posibles beneficios:

- Prolongar la vida.
- Aliviar el dolor causado por la angina de pecho.
- Aumentar el nivel de actividad o ejercicio del paciente.
- Permitir que el paciente realice actividades que había tenido que suspender debido a la angina de pecho.
- Reducir la necesidad de uso de medicamentos.
- Reducir los niveles de ansiedad/temor.

Posibles desventajas:

- Sangrado (hemorragia) que requiera más cirugía.
- Infección de la herida de la cirugía.
- Derrame (ataque) cerebral.
- Coágulos sanguíneos.
- Insuficiencia hepática (hígado), renal (riñón), o pulmonar.
- Ataque cardíaco.
- Muerte.

### ¿ Angioplastia o cirugía de puente coronario?

La cirugía y la angioplastia cumplen el mismo propósito, es decir, aumentar la irrigación de sangre al músculo del corazón. Su opción entre estos procedimientos depende de la gravedad de su condición.

¿ Cómo sabrá cuál es la mejor opción en su caso? El médico le recomendará el procedimiento más indicado y le ayudará a tomar una decisión. Pero, generalmente, la angioplastia:

- No es una cirugía mayor, como lo es la operación de puente coronario.
- Lo mantendrá en el hospital por menos tiempo.
- Le permitirá reanudar sus actividades de la vida diaria más rápido.

También es importante para su decisión que sepa que:

- En aproximadamente el 2 al 5 por ciento de los casos, la angioplastia no funciona, y el paciente tiene que someterse a la cirugía de puente coronario de emergencia.
- En aproximadamente 40 por ciento de los casos, las arterias se vuelven a bloquear dentro de los primeros 6 meses después de la angioplastia. Cuando esto sucede, el paciente tiene que volver a someterse a la angioplastia, o a una cirugía de puente coronario.

## Hablar con el personal médico a cargo de su cuidado

Muchos pacientes piensan que los médicos están demasiado ocupados para tomar tiempo para responder a sus preguntas, y otras personas no saben cómo hacer las preguntas para obtener información. En todos los casos de problemas de la salud, sin embargo el hablar con el médico, las enfermeras y otras personas a cargo de su cuidado es muy importante.

Sus preguntas son importantes y las personas a cargo de su cuidado médico tienen que tomar el tiempo para responder a sus inquietudes y dudas. Su opinión en cuanto a los tratamientos que preferiría recibir es muy importante en el proceso de tomar decisiones.

Probablemente le ayudará el ir a sus citas médicas acompañado de un familiar o amigo (especialmente alguien bilingüe en caso que el médico no hable español). Esta persona se puede asegurar que usted entienda toda la información, le puede ayudar a hacer preguntas y a hablar con el médico sobre los asuntos que le inquietan y sus preferencias en cuanto a las opciones de cuidado.

A continuación, algunas de las preguntas que puede hacer al médico antes de tomar la decisión en cuanto a su tratamiento.

- ¿ Qué es más recomendable en mi caso, el tratamiento con medicamentos, la angioplastia, o la cirugía de puente coronario?
- ¿ Cuál es la probabilidad que mis arterias se vuelvan a obstruir después de la angioplastia o la cirugía de puente coronario? ¿ Qué tan pronto puede suceder esto?
- ¿ Tendré que cambiar de trabajo o jubilarme?
- ¿ Cuándo puedo volver a realizar mis actividades de la vida diaria? ¿ Cuándo puedo volver a tener relaciones sexuales?
- ¿ Cuál es el costo de estos tratamientos médicos?
- ¿ Tengo que iniciar una dieta baja en sodio (sal) o grasas? Si es así ¿ Por cuánto tiempo?
- ¿ Sufriré un ataque cardíaco? ¿ Siempre tendré dolor de angina de pecho?

## ¿ Se pueden volver a obstruir las coronarias?

Ni la angioplastia ni la cirugía curan la angina de pecho. Los depósitos de grasa que pueden volver a obstruir las coronarias continúan produciéndose incluso después de estos tratamientos.

Ambos procedimientos se pueden volver a realizar si es necesario, pero la única manera de detener la enfermedad de las coronarias es prevenir las obstrucciones de las arterias.

Los médicos no han descubierto la razón por la que se forman las obstrucciones. Lo que sí saben, a través de estudios con números extensos de pacientes, es que existen algunas personas que tienen mayor riesgo de tener este problema.

Probablemente el médico recomendará que vaya a un programa de rehabilitación cardíaca. Generalmente los hospitales locales ofrecen estos programas y los seguros médicos pagan por los costos. En estos programas, los médicos, enfermeras, especialistas en actividad física y otros le ayudarán a cambiar las actividades y conductas de la vida diaria que hasta la fecha lo han puesto en alto riesgo para esta condición. Le enseñarán a hacer ejercicio físico sin riesgo a su condición cardíaca y a adaptar su vida a su enfermedad.

### La prevención de las obstrucciones

Las mejores formas de prevenir que se depositen grasas en las paredes de las coronarias son:

- Tomar aspirina diariamente;
- dejar de fumar;
- comer alimentos con bajo contenido de grasas;
- aumentar la actividad física (ejercicio);
- controlar la presión arterial, si ésta es alta;
- mantener un buen peso;
- menores niveles de tensión emocional.

## La vida diaria para las personas con enfermedades cardíacas

Es normal que se preocupe debido a su condición de salud y su futuro. Es importante que sepa que la mayoría de las personas que tienen angina de pecho no sufren de ataques cardíacos. Por lo general, la angina de pecho se estabiliza en aproximadamente 8 semanas. De hecho, las personas que reciben tratamiento para esta condición pueden vivir productivamente por muchos años.

La enfermedad de las coronarias no desaparece y sus hábitos de vida influyen su condición de salud. Por eso es tan importante seguir los consejos del médico y el resto del personal a cargo de su cuidado.

Cada año se les dice a miles de personas que tienen enfermedades de las coronarias. Esto puede sorprenderlo, especialmente si hasta la fecha nunca se ha sentido enfermo. Por esto, es común que la persona sienta temor, se preocupe por su futuro y su capacidad de cuidar a su familia. Esto hace que sienta que no tiene control sobre su vida. Muchos médicos, enfermeras, miembros del clero (iglesia), los consejeros y otros saben cómo ayudar a los pacientes con enfermedades de las coronarias. Ellos pueden ayudar a usted y su familia, es importante hablar con ellos sobre su condición física y mental. La mejor forma de volver a tomar control sobre su vida es aprender todo lo posible sobre las enfermedades de las coronarias y sus tratamientos. Hable sobre todas sus preguntas con el médico o la enfermera.

## ¿ Cómo puedo obtener más información sobre la angina de pecho inestable?

Las organizaciones que le pueden dar más información son: (Muchas de estas organizaciones ya cuentan con personal que puede hablar en español o publicaciones en este idioma. Cuando llame o escriba pregunte si lo pueden asistir en español.)

- American Heart Association
- 7272 Greenville Avenue
- Dallas, TX 75231-4596
- Teléfono gratuito 1-800-242-8721
- National Heart, Lung, and Blood Institute Information Center
- P.O. Box 30105
- Bethesda, MD 20824
- Teléfono: (301) 251-1222
- The Mended Hearts, Inc.
- 7272 Greenville Avenue
- Dallas, TX 75231-4596
- Teléfono: (214) 373-6300

El panel de la Guía sobre la angina de pecho inestable agradece la contribución de la Dra. Liliana Grinfeld. la Dra. Virginia Miller y Lucienne López-Loman en la traducción de la guía para el paciente.

## Para obtener más información

La información en esta publicación se obtuvo de la Clinical Practice Guideline on Unstable Angina . La guía fue desarrollada por un panel de expertos patrocinados por la Agency for Health Care Policy and Research (AHCPR), una agencia del Servicio de Salud Pública de los Estados Unidos. Existen y se están desarrollando otras guías para pacientes en inglés y en español sobre diversos problemas de la salud.

Para más información sobre las guías para el paciente o para recibir más copias de esta publicación, llame gratis al 1-800-358-9295, o escriba a:

- AHCPR Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907