# El control del dolor causado por el cáncer

## Datos sobre el tratamiento contra el dolor causado por el cáncer

Si usted está recibiendo tratamiento contra el dolor causado por el cáncer, es probable que tenga preguntas en cuanto a los medicamentos y los tratamientos existentes. A continuación, le presentamos algunos datos sobre los temas que causan inquietud entre los pacientes con cáncer.

- Tema: Sólo puedo tomar medicamentos y recibir otros tratamientos cuando tengo dolor.
- Hecho: No debe esperar hasta que el dolor sea severo antes de tomar los medicamentos. El dolor es más fácil de controlar cuando es leve que cuando es severo. Debe tomar los medicamentos regularmente como lo indique el médico. Puede ser que tenga que tomarlos regularmente durante las 24 horas del día. También puede usar otros tratamientos recomendados por el médico como los ejercicios de respiración y las compresas frías y calientes tan frecuentemente como usted quiera (vea las páginas 8 y 17)
- Tema: Me voy a hacer "adicto" (dependiente) a los medicamentos contra el dolor.
- Hecho: Los estudios científicos demuestran que es muy raro que los pacientes se hagan adictos a los medicamentos contra el dolor. Para controlar el dolor, es muy importante tomar los medicamentos regularmente.
- Tema: Con el tiempo, los medicamentos contra el dolor dejan de funcionar porque los pacientes desarrollan una "tolerancia" a sus efectos.
- Hecho: El desarrollar una "tolerancia" al medicamento no quiere decir que éste deje de funcionar. Esto no es un problema en el tratamiento del dolor causado por el cáncer porque probablemente lo que es necesario es cambiar la dosis (cantidad) o agregar otros medicamentos para lograr más alivio. Se le puede dar alivio contra el dolor, así es que no es necesario que sufra.
- Tema: Sólo los cobardes se quejan del dolor.
- Hecho: Muchos pacientes, sobre todo los hombres, piensan que hablar sobre su dolor es una señal de debilidad. De hecho, hablar sobre el dolor y su intensidad permite al médico encontrar los mejores tratamientos para aliviarlo. Los pacientes que no sufren dolor comen, duermen y descansan mejor, y todo esto ayuda en el tratamiento contra el cáncer.

Probablemente usted tiene otras inquietudes en cuanto al tratamiento que no se presentan en esta publicación. Si este es el caso, es importante que las discuta con su médico o enfermera.

## El propósito de esta publicación

Esta publicación presenta información sobre los mejores tratamientos existentes para controlar el dolor causado por el cáncer; aunque debe aclararse que no todas las personas que padecen esta enfermedad sufren de dolor.

Si sufre dolor causado por el cáncer, esta publicación le va a ayudar a:

- Entender que controlar el dolor es importante para su bienestar.
- Cooperar con su médico y enfermera para encontrar el mejor método para controlar el dolor en su caso.
- Hablar con el médico y la enfermera sobre su tratamiento para controlar el dolor, y determinar si éste le está ayudando.

## ¿Por qué es importante dar tratamiento contra el dolor?

El dolor le afecta de muchas maneras. Puede impedirle realizar actividades, dormir y comer bien, o disfrutar de la compañía de amigos y familiares. El dolor le puede hacer sentir temor y depresión. Su familia y amistades probablemente se preocuparán si notan que está sufriendo debido al dolor.

Con los tratamientos adecuados se pueden aliviar casi todos los tipos de dolor causados por el cáncer. Al sentir menos dolor, probablemente estará más activo e interesado en realizar las actividades que siempre ha disfrutado.

Si padece de cáncer y tiene dolor, es importante que se lo diga al médico o la enfermera de inmediato. Recibir tratamiento inmediato puede ayudar a que éste tenga mejores resultados.

## ¿Cuáles son las causas del dolor?

En el cáncer, el dolor es el resultado de muchas causas. En la mayoría de los casos, es debido a la presión de un tumor canceroso en los huesos, los nervios o los organos del cuerpo. Los tratamientos contra el cáncer también pueden provocar dolor.

También es posible que usted tenga dolores que no están relacionados en nada con el cáncer o su tratamiento. Como cualquier otra persona, probablemente a veces tiene dolores de cabeza, dolores musculares y otras dolencias. Debido a que probablemente usted estará tomando algún tipo de medicamento contra el dolor o contra el cáncer, es importante que consulte con el médico o la enfermera antes de usar cualquier otro remedio (incluyendo tés, hierbas, compresas, emplastos o infusiones).

Otros problemas de salud como la artritis también pueden causarle dolor. Puede ser que reciba tratamientos para estos problemas al mismo tiempo que lo tratan contra el cáncer. Nuevamente, es importante que hable con su enfermera o médico sobre sus antecedentes de salud. Ellos le podrán indicar los mejores tratamientos para cada uno de sus problemas de salud.

## El tratamiento contra el dolor causado por el cáncer

El tratamiento más común para aliviar el dolor causado por el cáncer son los medicamentos. Además de los medicamentos se pueden usar la cirugía, la radioterapia y otros tratamientos para dar mayor alivio contra el dolor (vea la lista en la página 8). Pregunte al médico o la enfermera si cualquiera de estos tratamientos podría ser útil en su caso.

## Seleccionar el medicamento adecuado

Los tratamientos contra el dolor tienen diferente efecto en cada paciente. Incluso cuando el médico recomienda el medicamento y tratamiento adecuados, puede ser que en su caso no resulte en el alivio necesario. Durante su tratamiento contra el dolor, es importante que hable con el médico sobre cómo se siente y si el tratamiento está surtiendo efecto. Esto permitirá encontrar las mejores alternativas.

Su médico y enfermera tratarán de encontrar los medicamentos más adecuados para aliviar su dolor, puede hablar con ellos sobre los siguientes temas:

- Los medicamentos contra el dolor que ha tomado en el pasado, y si éstos le han ayudado.
- Los tratamientos y medicamentos que toma para el cáncer y otros problemas de salud. Hable sobre todos los remedios que usa sin receta médica (incluyendo ciertos alimentos, vitaminas, tés, hierbas, emplastos, infusiones, compresas). Es importante que el médico y la enfermera sepan sobre estos tratamientos o medicamentos, ya que hay veces que éstos pueden causar problemas e interferir con el efecto del tratamiento médico principal. Sólo el médico o la enfermera le puede decir cuáles son los tratamientos contra el dolor más adecuados en su caso.
- Las alergias que padece, o si es alérgico a algún medicamento específico.
- Las preocupaciones e inquietudes que tiene en cuanto a los medicamentos o el tratamiento contra el cáncer. El médico puede responder a sus dudas y ayudarle a sentirse mejor.

## Tipos de medicamentos contra el dolor causado por el cáncer

Existen muchos medicamentos que se pueden usar en el tratamiento para aliviar el dolor causado por el cáncer y su médico le puede recetar uno o varios de ellos. La lista a continuación describe las diferentes categorías o tipos de medicamentos que probablemente le darán y el tipo de dolor que alivian. Pregunte al médico o enfermera los detalles sobre los medicamentos que le receten o recomienden.

No inicie el uso de ningún medicamento sin hablar con su médico o enfermera. Incluso la aspirina puede ocasionar problemas en algunos pacientes que están recibiendo tratamiento contra el cáncer.

- Para el dolor leve a moderado --
  - Medicamentos no derivados del opio (no opiáceos):
  - Acetaminofén o antiinflamatorios no esteroides, como la aspirina y el "ibuprofen". Puede comprar algunos de estos medicamentos sin necesitar una receta médica, otros de ellos tienen que ser recetados por el médico.

- Para el dolor moderado a severo --
  - Opiáceos (derivados del opio):
  - Morfina, hidromorfina, oxicodona, o codeína. Todos estos medicamentos se tienen que obtener con receta médica. Los medicamentos opiáceos y no opiáceos se pueden usar en combinación para el tratamiento del dolor moderado a severo.

- Para el dolor con picazón (hormigueante) o el dolor con ardor --
  - Antidepresivos:
  - Amipriptilina, imipramine, doxepina o trazodona. Todos estos medicamentos se tienen que obtener con receta médica. El usar estos medicamentos no quiere decir que usted padece de depresión o que tiene una enfermedad mental. Anticonvulsivos: Carbamazepina y fenitoína. Estos medicamentos se tienen que obtener con receta médica. El tomar estos medicamentos no quiere decir que usted podría tener convulsiones.

- Para el dolor causado por la hinchazón --
  - Esteroides:
  - Prednisona, dexametasona. Estos medicamentos se tienen que obtener con receta médica.

(Para más información sobre los medicamentos contra el dolor, vea las páginas 14 y 15.)

### Los efectos secundarios

Todos los medicamentos pueden causar efectos secundarios, pero éstos no necesariamente afectan a todas las personas. Los efectos secundarios afectan a cada paciente de diferentes maneras. La mayoría ocurren durante las primeras horas después que se ha iniciado el uso del medicamento y desaparecen gradualmente con el tiempo.

Algunos de los efectos secundarios más comunes de los medicamentos contra el dolor son los siguientes:

- Estreñimiento (no poder ir al baño). La mejor manera de evitar esta molestia es beber muchos jugos, agua, otros líquidos no alcohólicos, y comer más frutas y verduras. El ejercicio también lo ayudará. El médico o la enfermera le puede recomendar algún medicamento para suavizar el excremento, o un laxante.
- Náusea y vómito. Generalmente esto sólo sucede durante los primeros dos días después de iniciar el medicamento. Reporte al médico o la enfermera sobre estos problemas; ya que ellos le pueden dar algo para aliviarlos.
- Sueño. Algunos pacientes que toman medicamentos derivados del opio se sienten mareados y tienen sueño cuando inician el uso del medicamento, pero esto no dura mucho tiempo. Hable con el médico si tiene este problema.
- Ritmo de la respiración más lento. Esto por lo general sucede cuando se ha aumentado la cantidad de medicamento que tiene que tomar. Su médico o enfermera le puede decir qué esperar y cuándo es necesario que reporte este problema.

Los efectos secundarios más severos causados por los medicamentos para aliviar el dolor son poco frecuentes. Al igual que los otros problemas, sólo se presentan durante las primeras horas después de iniciar su uso e incluyen problemas para respirar, mareo e irritaciones de la piel. Si tiene cualquiera de estos problemas tiene que hablar con el médico o la enfermera de inmediato.

### Forma de administración (uso) de los medicamentos contra el dolor

La mayoría de estos medicamentos se toman en forma oral (por la boca), son fáciles de tomar y menos costosos que otros tipos de medicina. La mayoría de los medicamentos orales vienen en forma de tableta (pastilla) o en jarabe que puede beber. Si por alguna razón no puede tragar la tableta o el jarabe, existen otras maneras de administrar el medicamento. Estas incluyen las siguientes:

- Supositorios rectales (medicamentos que se introducen por el recto para que los absorba el cuerpo a través del intestino).
- Parches que contienen medicamento y se colocan en la piel para que los absorba el cuerpo (parches transdermales).
- Inyecciones. Existen muchos tipos de inyecciones para administrar los medicamentos para aliviar el dolor. La aguja de la jeringa se usa para introducir el medicamento al cuerpo. Puede ser de las siguientes maneras:
  - Inyección subcutánea:
  - El medicamento se administra justo debajo de la piel usando una aguja corta.
  - Inyección intravenosa:
  - El medicamento se administra directamente en la vena usando una aguja que permanece colocada en la vena (como un suero).
  - Epidural (intratecal):
  - El medicamento se administra directamente al interior de la columna vertebral usando un pequeño tubo.

Las inyecciones administran medicamentos para el dolor que le darán alivio por muchas horas.

- Las inyecciones intramusculares y subdermales:
- son aquéllas en las que la aguja penetra más profundamente en la piel o el músculo. El uso regular de estas inyecciones no es recomendable para el tratamiento prolongado del dolor causado por el cáncer; ya que el recibirlas frecuentemente puede causar molestias o dolor. También, el efecto de estas inyecciones puede tardar y el paciente tiene que esperar para sentir alivio.

### Cuándo tomar el medicamento contra el dolor

La siguientes recomendaciones probablemente ayudarán a que logre el mayor alivio con sus medicamentos contra el dolor:

- Tome los medicamentos con un itinerario (horario) constante. Tomar los medicamentos regularmente y seguir las instrucciones del médico le permitirá mantener el dolor bajo control. No olvide tomar ni siquiera una dosis del medicamento y no espere hasta que el dolor empeore antes de tomarlo.
- Tome una dosis adicional del medicamento antes de realizar una actividad que probablemente le causará dolor. Por ejemplo, algunos pacientes sienten más dolor cuando viajan en un automóvil. Consulte con su médico o enfermera en cuanto a tomar una mayor cantidad del medicamento. El propósito del uso de estos medicamentos es EVITAR que empiece el dolor; ya que una vez que ha empezado, es más difícil aliviarlo.

Dar tratamiento contra el dolor es importante y existen muchos medicamentos y tratamientos que se pueden usar. Si uno de ellos no ayuda en su caso, es posible encontrar otro que sea eficaz. También se pueden hacer cambios en el horario y administración del medicamento para encontrar el más adecuado para su caso.

Probablemente le ayudará mantener notas sobre la manera en la que le ha afectado o ayudado el medicamento. Mantener notas, como se indica en las páginas 18 y 19 le ayudará a hablar con el médico para encontrar los tratamientos más adecuados.

### Otros tratamientos

Para lograr más alivio del dolor, el médico y la enfermera probablemente recomendarán otros tratamientos que usará al mismo tiempo que los medicamentos. Los ejercicios de relajamiento (vea la página 17), las compresas frías, los cojines calientes, los masajes y el descanso pueden ayudar a reducir el dolor. La música o la televisión lo pueden distraer. Su familia y amigos le pueden ayudar a usar estos métodos y probablemente le ayudarán a que los medicamentos sean más eficaces. Recuerde que estos tratamientos no se usan para reducir la dosis de los medicamentos contra el dolor, sino como un complemento.

### Tratamientos no medicinales

Estos son algunos ejemplos de tratamientos que le pueden ayudar a aliviar el dolor. Úselos además de sus medicamentos regulares y consultando al médico o la enfermera:

- "Biofeedback" (una técnica en la que el paciente aprende a controlar su reacción al dolor con el uso de una máquina que le permite lograr mejor relajamiento).
- Ejercicios de respiración y relajamiento.
- Ejercicios de meditación.
- Masajes, puntos de presión, masajes de vibración.
- Estimulación transcutánea de los nervios (en inglés "TENS").
- Distracciones.
- Compresas frías o calientes.
- Descanso.

Hable con su médico o enfermera sobre estos tratamientos. Los servicios de apoyo y de consejería que se presentan en la página 16 también le darán información.

### cuando el medicamento contra el dolor no es suficiente

Algunos pacientes con cáncer no sienten el alivio necesario cuando toman medicamentos contra el dolor. cuando esto sucede, se pueden usar otros tratamientos para ayudarlos:

- Radioterapia. Este tratamiento proporciona alivio porque reduce el tamaño de los tumores. Para algunos pacientes, una sola dosis de radioterapia puede ser suficiente.
- Medicamentos para bloquear los nervios. Se inyecta medicamento directamente alrededor del nervio o en la columna vertebral (espina) para bloquear a los nervios que envían la señal de dolor al cerebro.
- Neurocirugía. Se cortan los nervios que transmiten el dolor (normalmente los que se encuentran en la columna vertebral).
- Cirugía. cuando el tumor presiona los nervios u otros órganos del cuerpo, la cirugía se usa para sacar parte o todo el tumor y así lograr alivio.

Hable con el médico sobre las mejores opciones en su caso.

## El primer paso

Lo más importante es que hable con su médico o enfermera sobre su tipo de dolor. Le preguntará cuanto dolor tiene, en dónde lo siente y exactamente cómo siente el dolor. Contestar las siguientes preguntas le ayudará a describir mejor su dolor. Probablemente deseará escribir las respuestas aquí para después dárselas al médico.

¿En dónde me duele? Probablemente le dolerá en más de un lugar del cuerpo. Es importante que anote todas las áreas del cuerpo en donde siente dolor.

¿Cómo siento el dolor? ¿Es un dolor persistente (que no se quita)? ¿Es un dolor pulsante (que aumenta y disminuye rítmicamente, como si fuera un latido)? ¿Es una picazón (hormigueo)? Trate de describir su dolor con éstas u otras palabras que le ayuden a explicarlo mejor.

¿Qué tanto dolor siento? Puede describir el dolor con un número en una escala de intensidad. La escala es del 0 al 10 y la puede encontrar en la página 19. El 0 quiere decir que no hay dolor, mientras que el 10 es el dolor más severo (fuerte). Dependiendo del grado de dolor que siente, puede usar la escala para describirlo. También puede describir la intensidad del dolor con palabras como leve (poco), medio, moderado, severo e intolerable (el peor dolor posible).

¿Qué reduce o aumenta el dolor? Probablemente usted ya ha encontrado maneras de reducir su dolor -- usando compresas frías o calientes, o tomando ciertos medicamentos. Probablemente también habrá notado que el sentarse o acostarse en ciertas posiciones, o realizar cierto tipo de actividades tiene un efecto en su dolor.

Si le están dando un tratamiento contra el dolor ¿qué tal está funcionando? Una manera de describir la eficacia del tratamiento es decir qué tanto ha reducido el dolor: Lo ha reducido totalmente, casi totalmente, no lo ha reducido, etc.

¿Ha cambiado el tipo de dolor? Probablemente notará que su dolor cambia con el tiempo. Puede mejorar o empeorar, o puede ser diferente. Por ejemplo, en un principio el dolor probablemente era persistente pero no muy severo (fuerte) y después cambió a una picazón (hormigueo). Los cambios en el tipo e intensidad del dolor son muy importantes, pero no necesariamente indican que el cáncer ha regresado o que haya crecido. Si ha notado cambios en el tipo de dolor, trate de describirlos al médico o la enfermera.

Después de hablar sobre su dolor, el médico probablemente lo examinará o recomendará rayos-x y otros exámenes. Esto le ayudará a encontrar la causa del dolor.

## Plan de tratamiento

Puede cooperar con el médico y la enfermera para desarrollar un plan de tratamiento que responda a sus necesidades. Junto con ellos puede planificar las actividades que puede utilizar para controlar el dolor. El plan incluirá un horario para tomar medicamentos, las ocasiones en las que tiene que tomar más medicamentos y otras alternativas que le permitan reducir o prevenir el dolor. El médico o la enfermera también le puede indicar los medicamentos o tratamientos que puede utilizar para los dolores causados por otros problemas de salud o para aliviar los efectos secundarios. En las páginas 20 y 21 hay un ejemplo de un plan de control del dolor.

### Encontrar un plan de tratamiento adecuado

Para algunos pacientes, el primer plan de tratamiento no es el más adecuado. Si este es su caso, hable con el médico ya que él puede cambiar el plan de tratamiento en cualquier momento. Las siguientes preguntas le pueden ayudar.

- ¿Le es difícil seguir las instrucciones del plan de tratamiento?
- ¿Hay algo que no entiende?
- ¿Le ha dado buen resultado el tratamiento?
- ¿Tiene problemas para obtener los medicamentos?
- ¿Tiene dificultad para tomar los medicamentos?
- ¿Ha tenido efectos secundarios provocádos por los medicamentos?
- ¿Ha tenido (usted o su familia) problemas debidos al tratamiento?
- ¿Le han ayudado los tratamientos no medicinales?
- Escriba otros comentarios o preguntas que le quiera hacer al médico o la enfermera.

## Beneficios y desventajas de los tratamientos

Esta publicación presenta información sobre diferentes tratamientos para controlar el dolor causado por el cáncer y los efectos secundarios de los medicamentos que se utilizan. La información sobre los beneficios y posibles desventajas (efectos secundarios) también puede ser importante para usted. La siguiente lista describe los beneficios y desventajas de los medicamentos que se presentan en las páginas 4 y 5.

### Medicamentos no derivados del opio (no opiáceos)

- Beneficios:
- Controlan el dolor leve o moderado. Algunos se pueden comprar sin receta médica.
- Desventajas:
- Algunos de estos medicamentos le pueden dar molestias en el estómago. También pueden causar sangrado (hemorragia) del estómago, problemas para la coagulación de la sangre, o problemas del riñón. El acetaminofén no causa estos problemas.

### Medicamentos derivados del opio

- Beneficios:
- Controlan el dolor moderado a severo y no causan sangrados.
- Desventajas:
- Pueden causar estreñimiento (no poder ir al baño), sueño, náusea y vómito. También pueden causar problemas al orinar, o comezón (picazón). Pueden reducir el ritmo de la respiración, especialmente cuando se inicia su uso; pero este problema es poco común entre los pacientes que consumen estos medicamentos regularmente.

### Antidepresivos

- Beneficios:
- Pueden ayudar a controlar el dolor con picazón (hormigueante) o de ardor causado por el daño a los nervios. También ayudan al paciente a dormir mejor.
- Desventajas:
- Pueden causar sequedad en la boca, sueño y estreñimiento (no poder ir al baño). Algunos causan mareo o sensación de desmayo cuando el paciente se levanta o se mueve rápidamente.

### Anticonvulsivos

- Beneficios:
- Ayudan a controlar la picazón (hormigueo) y el ardor causado por el daño a los nervios.
- Desventajas:
- Pueden reducir la función del hígado y el número de células rojas y blancas de la sangre. Es importante que le hagan exámenes de la sangre para revisar que no haya problemas por estos efectos secundarios.

### Esteroides

- Beneficios:
- Ayudan a aliviar el dolor en los huesos, el dolor causado por tumores en la médula espinal o en el cerebro, y el dolor causado por la inflamación. Los esteroides también aumentan el apetito.
- Desventajas:
- Pueden causar retención de líquidos en el cuerpo. Pueden irritar y causar sangrado en el estómago. La confusión mental también puede ser un efecto secundario para algunos de los pacientes que toman esteroides.

## Consejería y servicios de apoyo

El dolor puede provocar muchas emociones como tristeza, sentirse desvalido, vulnerabilidad, furia, depresión, soledad, aislamiento y otros. Frecuentemente, cuando se da tratamiento exitoso contra el dolor, estos sentimientos desaparecen. Muchos pacientes con cáncer opinan que los servicios de consejería, el apoyo religioso, y otros grupos de apoyo ayudan al individuo y su familia a recuperar una sensación de control y bienestar.

Para obtener más información sobre grupos de apoyo y para recibir publicaciones sobre el dolor causado por el cáncer diríjase a: (Muchas organizaciones ya cuentan con servicios y publicaciones en español, no se olvide de preguntar por los servicios en este idioma.)

- National Cancer Insitute
  - Cancer Information Service
  - 800-422-6237
  - Pida questions and Answers About Pain Control.
  - (Este servicio cuenta con personal que habla español.)
- American Cancer Society
  - 800-227-2345
  - (en el directorio telefónico de su comunidad también encontrará un número local).
  - Pida questions and Answers About Pain Control.

## Ejercicios de respiración para el relajamiento

Los ejercicios de respiración profunda le pueden ayudar a relajarse. Junto con su medicamento, estos ejercicios pueden ayudarle a controlar el dolor.

1. Respire lenta y profundamente.
2. cuando expire (saque el aire), sienta cómo se relaja su cuerpo, sienta la tensión saliendo de su cuerpo.
3. Ahora respire y expire lenta y rítmicamente de una manera que le sea natural.
4. Para ayudar a que se concentre en su respiración y para respirar lenta y rítmicamente: a) Tome aire diciendo en silencio "respirar, uno, dos." b) Expire diciendo en silencio "expirar, uno, dos."
  - O también, cada vez que expire, diga en silencio una palabra que le ayude a relajarse como "paz" o "tranquilidad".
5. Realice los pasos 1 al 4 sólo una vez, y repita los pasos 3 y 4 hasta por 20 minutos.
6. Finalmente, suspire lenta y profundamente. Diga en silencio "Me siento tranquilo(a) y relajado(a)."

Fuente: McCaffery and Beebe, 1989. Adaptado y reimpreso con permiso.

## Tabla del uso de medicamentos para el control del dolor

Puede usar la siguiente tabla para tomar notas del efecto de sus medicamentos para aliviar el dolor. Use la escala del dolor para definir la intensidad.

Intensidad del dolor 

 0     1     2    3    4    5    6    7    8    9    10 
|------------------------------------------------------|
 No hay               Dolor moderado          Dolor severo
 dolor                   (medio)                 (mucho)

Fecha | Hora | Número de intensidad del dolor de acuerdo ala escala. | Nombre del medicamento | Número de intensidad del dolor de acuerdo a la escala (después de una hora de haber tomado el medicamento) | Actividad(es) que me causaron dolor.
1/3/94 | 2:35 | 6 | dos aspirinas | 3 | Sentado leyendo un libro.
----- | ----- | ----- | ----- | ----- | -----
----- | ----- | ----- | ----- | ----- | -----
----- | ----- | ----- | ----- | ----- | -----

## Plan de control del dolor

En casa, tomaré los siguientes medicamentos para controlar el dolor

Medicamento | Cómo tomarlo | Cuánto(s) | Cuándo | Comentarios
---- | ---- | ---- | ---- | ----
---- | ---- | ---- | ---- | ----
---- | ---- | ---- | ---- | ----

Medicamentos que puede tomar para el tratamiento de los efectos secundarios

Efecto Secundario | Medicamento | Cómo tomarlo | Cuánto(s) | Cuándo | Comentarios
---- | ---- | ---- | ---- | ---- | ----
---- | ---- | ---- | ---- | ---- | ----
---- | ---- | ---- | ---- | ---- | ----

El estreñimiento es el problema más común cuando se toman medicamentos derivados del opio. cuando esto suceda, haga lo siguiente:

- Tome más líquidos no alcohólicos (8 a 10 vasos al día).
- Haga ejercicio regularmente.
- Aumente los alimentos fibrosos (cereales integrales, fruta fresca y verduras).
- Use laxantes suaves, como la leche de magnesia, si no ha ido al baño en 3 días.
- Tome________diariamente a las ________(hora) con un vaso de agua.
- Use un supositorio de glicerina cada mañana (esto puede ayudar a que no le duela cuando trate de ir al baño).

Métodos no medicinales para controlar el dolor:

Otras instrucciones:

Números de teléfono importantes:

Mi médico:

Mi enfermera(s):

Mi farmacia:

En caso de emergencias:

Llame al médico o la enfermera de inmediato si aumenta el dolor, o si siente un dolor que antes no tenía. No olvide llamar con anticipación al médico para que le dé una receta para comprar más medicamentos. Nunca deje que su ración de medicamento sea menor que lo que necesitará para 3 o 4 días.

## Para obtener más información

La información en esta publicación se obtuvo de la Clinical Practice Guideline on Management of Cancer Pain. La guía fue desarrollada por un panel de expertos patrocinados por la Agency for Health Care Policy and Research (AHCPR), una agencia del Servicio de Salud Pública de los Estados Unidos. Existen y se están desarrollando otras guías para pacientes en inglés y en español sobre diversos problemas de la salud. Para más información, o para recibir más copias de esta publicación, llame gratis al 1-800-422-6237, o escriba a:

- AHCPR Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907