# Tratamientos para la inflamación (crecimiento) benigna de la próstata

## ¿Qué es la próstata?

La próstata es la glándula del hombre que produce parte del líquido lechoso (semen) en el que fluyen los espermatozoides para la reproducción. La próstata es del tamaño de una nuez y se encuentra debajo de la vejiga, que es en donde se acumula la orina. La próstata rodea a la uretra, que es el tubo que conduce la orina hacia la salida del pene (vea el dibujo).

Sistema urinario del hombre

cuando el hombre tiene un orgasmo (satisfacción o clímax sexual), el esperma de los testículos y el líquido lechoso que produce la próstata entran en la uretra. El líquido transporta a los espermatozoides a través del pene.

## El propósito de esta publicación

Esta publicación le ayudará a entender la inflamación (hiperplasia) benigna de la próstata y sus tratamientos. La inflamación de la próstata es una condición común en la que crece la próstata. La condición es común entre los hombres de edad mayor, pero a veces no causa ningún problema. Si usted tiene que decidir en cuanto a un tratamiento, esta publicación le explica los beneficios y las posibles desventajas de los tratamientos existentes.

## Definición del problema

### ¿Qué es la inflamación benigna de la próstata?

Es una condición en la que la próstata crece a un tamaño más grande de lo normal.

La inflamación de la próstata no es una condición cancerosa y no causa cáncer.

Nota: La definición clínica de inflamación no es el significado preciso para el término "hiperplasia", esta palabra se usa para facilitar la lectura del lector promedio.

La palabra "benigna" quiere decir que las células no son cancerosas; y la palabra "hiperplasia" quiere decir que existen más células de lo normal.

La probabilidad de que usted tenga problemas con la próstata aumenta con su edad y no se puede prevenir. La condición es más común entre los hombres mayores de los 50 años. Por ejemplo, más de la mitad de los hombres mayores de 60 años la padecen, y 8 de cada 10 hombres mayores de 80 años la presentan.

No es una condición cancerosa.

La inflamación de la próstata no siempre causa problemas. Menos de la mitad de los hombres que la tienen presentan síntomas; y sólo algunos de los que sí presentan síntomas necesitarán recibir tratamiento.

### ¿Cuáles son los síntomas de la inflamación benigna de la próstata?

Muchos hombres que tienen la condición no presentan síntomas molestos. Entre los que la tienen, el síntoma más común es tener problemas para orinar. Marque ( X ) los síntomas que usted presenta:

- Siento que no puedo vaciar totalmente mi vejiga cuando termino de orinar.
- Orino frecuentemente.
- cuando orino, el flujo empieza y se detiene varias veces.
- Siento una necesidad urgente de orinar, quees difícil de aguantar.
- Mi flujo de orina es muy débil.
- Para empezar a orinar, tengo que hacer mucho esfuerzo y empujar.
- Durante la noche, me despierto con la necesidad de orinar.

### ¿Qué causa los síntomas?

Conforme crece la próstata, ésta presiona el tubo de la uretra haciéndolo más estrecho. Este tubo más estrecho es lo que hace difícil orinar. A veces la inflamación de la próstata también puede causar infección o sangrado.

Durante las primeras etapas de la inflamación de la próstata, el paciente puede orinar con un mayor esfuerzo del músculo de la vejiga; empujando la orina a través del tubo estrecho de la uretra. Pero conforme progresa la condición, el músculo de la vejiga se va haciendo más fuerte, grueso y sensible.

Esto es lo que causa la sensación urgente de tener que orinar.

En algunos casos, el paciente puede tener problemas al tratar de empujar la orina a través de la uretra, así es que no puede vaciar completamente su vejiga. En algunos otros casos, el paciente repentinamente no puede orinar (una condición conocida como retención de orina aguda). Con el transcurso del tiempo, algunos de los pacientes pueden presentar problemas de la vejiga o del riñon, o ambos.

En los casos en que se presenta una infección del sistema urinario, el paciente tiene una sensación de ardor y dolor al orinar. (El sistema urinario se deshace de la orina e incluye los riñones, uréteres, vejiga, y uretra [vea el dibujo]).

## ¿Cuándo debe visitar al médico?

Si tiene cualquier síntoma que le causa molestias, debe visitar al médico para que determine cuál es el problema, ya sea el crecimiento de la próstata o alguna otra enfermedad. Si usted tiene inflamación de la próstata, el médico también podrá determinar si ésta le ha causado otros problemas de salud.

## ¿Cómo se diagnostica la inflamación de la próstata?

Para diagnosticarle, el médico probablemente hará lo siguiente:

- Le hará preguntas sobre sus síntomas. estas preguntas son importantes ya que le ayudarán a decidir si su problema es leve, moderado o severo.
- Le preguntará sobre sus antecedentes médicos. Hablarán sobre otros problemas de salud que ha padecido.
- Le examinará la próstata. Usando un guante con lubricación, palpará su próstata a través del recto.
- Le hará un examen físico general. Para determinar si alguna otra condición le está provocando los problemas.
- Revisará su orina. Para determinar si ésta tiene sangre u otras señales de infección (este examen se conoce como examen de orina).
- Le hará un examen de la sangre. Para determinar si el problema de la próstata ha llegado a afectar sus riñones. Probablemente el médico también recomendará un análisis de la sangre para detectar el cáncer de la próstata.

Estos exámenes no son molestos o costosos y ayudan a confirmar si usted tiene crecimiento de la próstata y los problemas que le ha causado. Sin embargo, si no recibe tratamiento ahora, estos exámenes no pueden predecir si la condición le provocará otros problemas en el futuro.

Su médico también le recomendará otros exámenes para determinar si la condición ha afectado su vejiga o sus riñones. También es necesario asegurarse de que los problemas no son el resultado del cáncer. Estos exámenes pueden ser de ayuda para algunos pacientes, pero no para todos:

- La prueba de flujo de la orina mide la rapidez y cantidad de orina que pasa por la uretra y determina el grado de bloqueo que se presenta.
- La prueba de residuo de orina mide la cantidad de orina que queda en la vejiga después que el paciente ha orindo y determina el efecto de la condición en la vejiga. Existen varios métodos para realizar esta prueba y usted y su médico deben hablar sobre el método más adecuado en su caso.
- Las pruebas de presión y flujo ayudan a determinar la presión que ejerce en su vejiga mientras orina. Algunos médicos piensan que éste es el mejor método para determinar el grado de bloqueo. estas pruebas ayudan a clarificar los resultados de otros exámenes; o si el médico piensa que el paciente probablemente tiene problemas de la vejiga. Para realizar esta prueba, se introduce un pequeño tubo o catéter a través del pene y la uretra hasta la vejiga. Puede causar un poco de molestia y en algunos pacientes puede causar una infección urinaria.
- El examen de antígeno específico de la próstata es un examen de la sangre que ayuda a detectar el cáncer de la próstata. Como se ha dicho, la inflamación de la próstata no causa el cáncer, pero algunos hombres que la tienen pueden padecer de cáncer al mismo tiempo. Este examen de sangre no siempre es preciso y a veces puede indicar equivocadamente que un paciente tiene cáncer. A veces también puede indicar equivocadamente que un paciente que padece de cáncer no lo tiene. No todos lo médicos están de acuerdo que el recibir el examen de antígeno específico reduce la probabilidad de que un paciente muera de cáncer de la próstata. Cada caso es diferente, así que usted debe hablar directamente con su médico.

Probablemente su médico recomendará otros exámenes como rayos-x, cistoscopia, o ultrasonido. Muchos pacientes no necesitan hacerse estos exámenes que son costosos y no necesariamente útiles. Los rayos-x y la cistoscopia pueden causar problemas en algunos pacientes. Sin embargo, pueden ayudar a diagnosticar algunos problemas relacionados con la inflamación de la próstata, y ayudan a pacientes que tienen problemas tales como sangre en la orina.

- La cistoscopia le permite al médico mirar directamente dentro de la próstata y la vejiga. Si su médico y usted deciden que es necesaria una cirugía, este procedimiento permite decidir el tipo de operación más adecuada en su caso. Durante el examen se introduce un tubo a través del pene y la uretra hasta la vejiga. Algunos pacientes tienen molestias durante y después del examen. Algunos pueden presentar infecciones urinarias o sangre en la orina, y algunos pueden dejar de orinar por un corto período después del examen.
- Un rayos-x conocido como urograma permite que el médico vea el bloqueo en el ducto urinario. Durante el examen se inyecta una sustancia de contraste (tinte) en las venas que permite que se vea el sistema urinario en las radiografías. Algunos pacientes son alérgicos a estas sustancias.
- El ultrasonido permite que el médico vea la próstata, los riñones y la vejiga sin la necesidad de usar un catéter o rayos-x. Un instrumento que se coloca sobre la piel envía ondas de sonido (ultrasonido) hacia el cuerpo. Los ecos producen imágenes de televisión de la próstata, los riñones o la vejiga. Este examen no causa molestias o daño. Para producir una mejor imagen de la próstata, se introduce un instrumento especial en el recto. Esto último se hace cuando el médico sospecha que existe cáncer de la próstata.

## ¿Cuándo es apropiado dar tratamiento?

Solamente es necesario dar tratamiento cuando:

- Los síntomas son lo suficientemente severos para causarle molestias.
- Si la condición ha afectado seriamente el sistema urinario.

Tener la próstata inflamada no es razón suficiente para recibir tratamiento. Es posible que su próstata no se inflamará más de lo que está en este momento y sus síntomas no empeorarán.

Hágase las siguientes preguntas en cuanto a sus síntomas:

- ¿Le impiden realizar actividades que usted disfruta, como acudir a eventos deportivos o practicar algún deporte?
- ¿Realizaría más actividades si no tuviera los síntomas?
- ¿Quiere que le den tratamiento ahora mismo?
- ¿Está dispuesto a correr algunos riesgos a su salud para mejorarse de los síntomas?
- ¿Sabe cuáles son los riesgos?

Las respuestas a las preguntas anteriores le pueden ayudar a elegir un tratamiento adecuado en su caso.

Los pacientes bien informados toman las mejores decisiones.

## ¿Cuáles son las opciones de tratamiento?

Actualmente existen cinco tratamientos para la inflamación de la próstata:

- Esperar sin dar tratamiento, sólo bajo observación médica.
- Tratamiento con un medicamento conocido como "bloqueador alfa".
- Tratamiento con un medicamento conocido como "finasteride".
- Dilatación con el uso de un globo (balón).
- Cirugía (una operación).

La cirugía es el mejor tratamiento para aliviar sus síntomas al orinar, pero al mismo tiempo tiene más riesgos que los demás tratamientos. Usted puede optar por varios tratamientos, y debe elegir la cirugía sólo cuando sufre complicaciones serias debidas al crecimiento de su próstata que hacen necesaria una operación. El tipo de tratamiento que elija depende de qué tanto le molestan los síntomas. Su decisión también depende de qué tanto riesgo está dispuesto a correr para aliviarse de los síntomas. Usted y su médico pueden decidir la mejor opción en su caso.

### Sólo bajo observación médica

Si no presenta síntomas molestos, usted y su médico probablemente decidirán esperar sin dar tratamiento, es decir que no tomará ningún medicamento ni le harán una operación. Lo que le harán es un examen cada año, para determinar si la inflamación de su próstata ha empeorado o si causa otros problemas. El médico le preguntará si tiene algún otro problema y probablemente le recomendará algunos otros exámenes médicos para determinar si su condición le ha afectado los riñones o la vejiga.

Los problemas serios son poco comunes entre los pacientes que deciden no tener tratamiento. Estos incluyen infecciones, sangrado, o daño a los riñones y la vejiga. Unos pocos pacientes dejan de poder orinar.

Algunas de las recomendaciones del médico para controlar la condición son que el paciente beba menos líquidos antes de acostarse. También les aconsejan que no tomen medicamentos para el tratamiento de problemas de sinusitis y congestión nasal sin supervisión médica; ya que estos medicamentos pueden empeorar la condición de la próstata.

Los síntomas de los pacientes que no reciben tratamiento pueden mantenerse iguales, mejorar o empeorar. Si usted nota que su condición empeora, hable con su médico sobre las alternativas de tratamiento.

### Tratamiento con medicamentos "bloqueador alfa"

Los bloqueadores alfa se toman por la boca una o dos veces al día. Estos medicamentos relajan los músculos en la próstata, de tal manera que algunos pacientes notan una mejoría en sus síntomas al orinar.

Probablemente el médico le verá con más frecuencia durante las 3 o 4 primeras semanas para asegurarse que el tratamiento va bien. El revisará sus síntomas y la dosis del medicamento (cuánto y cuándo lo toma). Después de esto, las visitas serán menos frecuentes, y entonces el médico lo revisará y le dará una receta médica para obtener más medicamento. No existe evidencia que los medicamentos bloqueadores alfa reduzcan el porcentaje de complicaciones causadas por la inflamación de la próstata o la probabilidad de que se tenga que hacer cirugía en el futuro.

Los efectos secundarios incluyen dolores de cabeza, mareo, cansancio o una baja en la presión de la sangre. Debido a que el uso de bloqueadores alfa es reciente, los médicos aún no conocen los riesgos y beneficios a largo plazo.

Los bloqueadores alfa incluyen el "doxozosin" ("Cardura"), el "prazosin" ("Minipress"), y el "terazosin" ("Hytrin;"). "Hytrin;" es el único medicamento bloqueador alfa aprobado por La Administración Federal de Alimentos y Drogas para el tratamiento de la inflamación de la próstata.

### Tratamiento con el medicamento "finasteride"

El finasteride ("Proscar") es un medicamento que se toma por la boca una vez al día para reducir el tamaño de la próstata. Algunos pacientes notan una mejoría en sus síntomas para orinar. Pueden pasar 6 meses o más antes que usted note todos los beneficios del medicamento y es necesario que visite a su médico regularmente mientras que lo siga tomando. No existe evidencia que el medicamento "finasteride" reduzcan el porcentaje de complicaciones causadas por la inflamación de la próstata o la probabilidad de que se tenga que hacer cirugía en el futuro.

Este también es un nuevo tratamiento, así es que los médicos aún no conocen los beneficios y riesgos a largo plazo. El finasteride reduce el nivel del antígeno específico de la próstata en la sangre; de tal manera que los médicos no saben si esto puede afectar los resultados del examen de sangre para detectar el cáncer de la próstata.

Los efectos secundarios del finasteride incluyen menor interés en tener relaciones sexuales, problemas en lograr una erección, y problemas para eyacular.

### Dilatación con el uso de un globo (balón)

La dilatación se realiza en una sala de operaciones o en la oficina de un médico. Se le da anestesia al paciente (para que no sienta dolor) y el doctor inserta en el pene un catéter (tubo) con un globito desinflado en la punta. El catéter se pasa a través del pene y la uretra hasta la vejiga.

El médico infla el globito que, a su vez, abre la uretra en el lugar que ésta ha sido presionada por la próstata. Esto ayuda a algunos pacientes a orinar mejor.

El procedimiento puede causar sangrado o infección y algunos pacientes no pueden orinar por un período de tiempo. Si no hay ningún problema, el paciente puede irse a casa el mismo día, pero algunos pacientes se tienen que quedar en el hospital por una noche.

La dilatación es un procedimiento relativamente nuevo y los médicos aún no conocen sus beneficios y riesgos a largo plazo. En muchos de los pacientes este tratamiento sólo funciona por un corto período de tiempo.

### Cirugía

La cirugía para tratar esta condición se ha realizado por muchos años, así es que los médicos conocen bastante bien los riesgos y beneficios. En comparación con los demás tratamientos, la cirugía da resultados más rápidos, pero también es más probable que cause problemas serios. Sin embargo, la mayoría de los hombres que se someten a la cirugía no presentan problemas.

El tener inflamación de la próstata no necesariamente quiere decir que necesita una operación, ya que es posible que la próstata no se inflamará más. Además, la operación para esta condición no tiene ningún efecto en la probabilidad de que el paciente padezca de cáncer de la próstata en el futuro.

La cirugía se recomienda en casi todos los casos en que los pacientes tienen los siguientes síntomas:

- No pueden orinar.
- Bloqueo y acumulación de orina que llega hasta los riñones y los daña.
- Infecciones urinarias frecuentes.
- Sangrado severo a través de la uretra (causado por el crecimiento de la próstata).
- Cálculos (piedras) en la vejiga.

Si usted no padece de estos problemas serios, pero aún tiene molestias causadas por el crecimiento de la próstata, probablemente considerará la posibilidad de la cirugía.

Existen tres tipos de cirugía:

- Resección transuteral de la próstata.
- Incisión transuteral de la próstata.
- Prostatectomía (una operación a través del abdomen).

La operación de resección transuteral es la operación más común y se ha comprobado que es eficaz en el tratamiento del crecimiento de la próstata. El paciente mejora cuando la operación reduce la presión de la próstata en la uretra.

Después de anestesiar al paciente, sin tener que cortar la piel, el médico introduce un instrumento especial a través del pene y hasta la uretra. Con este instrumento, el médico saca parte de la próstata.

Después de la cirugía el paciente tiene que usar una sonda para drenar la orina por 2 o 3 días y probablemente tendrá que quedarse en el hospital por ese período. La mayoría de los pacientes notan una pronta mejoría después de la cirugía y permanecen bien por muchos años.

La operación de incisión transuteral se puede recomendar cuando la próstata no está tan inflamada. En esta cirugía no se saca ningún tejido. Se introduce un instrumento a través de la uretra y se realizan dos pequeños cortes en la próstata. Estos cortes reducen la presión de la próstata en la uretra y ayudan a que el paciente pueda orinar. En ciertos casos esta cirugía tiene menores riesgos que la anterior.

La prostatectomía se usa cuando la próstata está muy crecida. Se realiza una incisión en la parte baja del abdomen del paciente y se saca parte del interior de la próstata.

La cirugía mejora los síntomas de la inflamación de la próstata en la mayoría de los pacientes, pero algunos síntomas pueden persistir. Por ejemplo, los músculos de la vejiga pueden quedar débiles después de la operación y esto quiere decir que el paciente probablemente seguirá teniendo problemas para orinar.

### Nuevos tratamientos

Cada año surgen nuevos tratamientos como la cirugía con rayos láser, cirugía termal con microondas, férula prostática y nuevos medicamentos. La cirugía de rayos láser presenta los riesgos de cualquier cirugía y los médicos aún no saben si los beneficios y los riesgos de ésta son mayores o menores que los de las cirugías ya conocidas.

Aún no existe información definitiva que podamos incluir en esta publicación sobre estos y otros nuevos tratamientos. Si su médico recomienda un tratamiento nuevo, pídale que le explique los riesgos y beneficios de cada uno de la misma manera en la que se le presentan a continuación sobre los tratamientos ya conocidos.

## ¿Cuáles son los beneficios y los riesgos?

Cada uno de los tratamientos puede mejorar sus síntomas, pero cada uno de ellos tiene diferentes probabilidades de éxito. Todos los tratamientos, incluyendo la decision de no dar tratamiento, tienen algunos riesgos.

Hágale al médico las siguientes preguntas sobre cada uno de los tratamientos:

- ¿Cuál es la probabilidad de mejorar?
- ¿Qué tanto mejoraré?
- ¿Cuáles son las probabilidades de que el tratamiento me cause problemas?
- ¿Por cuánto tiempo funcionará el tratamiento?

A continuación se presentan los beneficios y los riesgos de cada tratamiento para que los pueda consultar con su médico.

La Tabla 1 muestra que la probabilidad de que mejoren sus síntomas con la cirugía de resección transuteral es mejor que si decide que no le den tratamiento (sólo observación médica).

Incluso con la resección, sus probabilidades de mejoría no son definitivas. Esto es asi porque los médicos no pueden saber las probabilidades exactas de mejoría de cada paciente. Por lo general, los pacientes que presentan la mayor mejoría después del tratamiento son los que tenían los peores síntomas. El éxito de la incision transuteral y la prostatectomía son similares a los de la resección transuteral.

Tabla 1. Mejoría de los sitomás con cada tratamiento

La Tabla 2 muestra el grado de mejoría de los síntomas con cada uno de los tratamientos. Nuevamente la resección proporciona la mayor mejoría, mientras que la observación médica da la menor mejoría.

Tabla 2. Grado de mejoría de los sitomás con cada tratamiento

La Tabla 3 muestra las probabilidades de que se presenten problemas durante o poco después que se proporciona el tratamiento.

Tabla 3. Probabilidad de problemas inmediatos de cada tratamiento

En la mayoría de los casos, los tratamientos no ocasionan problemas y aquéllos que se presentan no son serios. Algunos de los problemas serios de la resección transuteral son: enfermedad del corazón, sangrado que requiere una transfusión, o bloqueo del flujo de la orina. Sólo unos pocos de los pacientes de la cirugía tienen estos problemas (vea la tabla en las páginas 24 y 25).

Los efectos secundarios más comunes de los pacientes que toman los medicamentos bloqueadores alfa son mareo, cansancio y dolores de cabeza.

El finasteride causa problemas sexuales tales como un menor deseo sexual o problemas para lograr una erección en aproximadamente 5 de cada 100 pacientes.

Con la observación médica sin tratamiento no existe la probabilidad de que se presenten problemas de inmediato, pero el crecimiento mismo puede hacer que los síntomas empeoren, o causar otros problemas. Solamente la resección transuteral reduce significativamente este riesgo. Los doctores no saben si los medicamentos bloqueadores alfa, el finasteride, o la dilatación con globo pueden reducir las probabilidades de problemas futuros causados por la inflamación de la próstata.

Recibir sólo una cuidadosa observación médica es lo indicado para muchos pacientes.

La Tabla 4 muestra las probabilidades de morir como resultado del tratamiento. Probablemente no hay mayor riesgo de morir con sólo la observación médica, los medicamentos bloqueadores alfa y el finasteride. No existe información a este respecto con el uso de la dilatación con globo.

Tabla 4. Probabilidad de morir durante los 3 meses después del tratamiento

La edad promedio de los pacientes que padecen de inflamación benigna de la próstata es 67 años. La probabilidad que una persona de esta edad muera por cualquier razón es de aproximadamente 8 en 1,000 en un período de tres meses. Existe una muy pequeña probabilidad de morir dentro de los tres meses después de la operación de resección transuteral (15 de cada 1,000) pacientes. Si usted tiene buena salud general, la probabilidad de morir debido a la cirugía es aún más baja.

Algunos de los tratamientos para la inflamación de la próstata pueden causar incontinencia urinaria, es decir, orinar cuando usted no lo quiere. Con el tiempo, el mismo crecimiento de la próstata puede ocasionar este problema de incontinencia urinaria. Los pacientes que reciben el tratamiento con bloqueadores alfa, finasteride, o la dilatación con globo también tienen el riesgo de tener incontinencia urinaria en el futuro.

Raramente, algunos pacientes presentan incontinencia urinaria severa después de recibir tratamiento (vea la Tabla 5). Aproximadamente entre 7 a 14 pacientes de cada 1,000 tienen este problema después de la operación de resección transuteral. Sólo los pacientes que no reciben tratamiento no presentan este problema.

Tabla 5. Probabilidad de tener incontinencia urinaria (orinar sin quererlo)

La probabilidad de tener que hacerse una operación en el futuro varía de un tratamiento a otro. Algunos de los pacientes que en un principio eligen sólo la observación médica sin tratamiento, o que usan medicamentos, pueden decidir más tarde que quieren hacerse la cirugía para aliviar los síntomas molestos. Algunas veces, los pacientes que ya se han hecho una operación necesitan otra más porque la próstata vuelve a crecer. Otra razón es que el tejido de cicatrización de la primera cirugía bloquea el ducto urinario.

En el transcurso de los primeros 8 años después de la operación de resección, entre 5 a 15 pacientes de cada 100 necesitarán otra cirugía. Los médicos no están seguros de que el uso de los tratamientos con bloqueadores alfa, finasteride o la dilatación con globo reduzcan la probabilidad de que los pacientes necesiten la cirugía en el futuro.

La Tabla 6 muestra la posibilidad de sufrir de impotencia sexual (no poder tener una erección) debido al tratamiento para la inflamación de la próstata. Cada año, aproximadamente 2 de cada 100 hombres de 67 años de edad se vuelven impotentes, aunque no padezcan de la condición y, por lo tanto no reciban ningún tratamiento.

Tabla 6. Impotencia sexual (no tener erecciones)

Probablemente no hay mayor riesgo de impotencia entre los pacientes que están sólo bajo observación médica o los que usan los medicamentos bloqueadores alfa. Los que usan el finasteride tienen un riesgo un poco más alto de sufrir de impotencia, pero el problema se debe aliviar después de suspender el medicamento. El riesgo para los pacientes de dilatación por globo es desconocido, pero probablemente bajo. Finalmente, la probabilidad de impotencia para los pacientes de la cirugía de resección es de entre 3 a 35 de cada 100.

Para la mayoría de los pacientes de la operación que tienen función sexual normal, el riesgo probablemente no es más alto que el de los pacientes que no reciben ningún tratamiento.

La Tabla 7 muestra el número de días de incapacidad que probablemente tendrá que tomar de su trabajo o de su vida normal durante el primer año después de recibir el tratamiento. Esto incluye el tiempo que necesita para visitar al médico y los servicios en el hospital.

Tabla 7. Tiempo de incapacitación durante el primer año despué del tratamiento

También se puede presentar otro problema conocido como eyaculación inversa. Este problema es común con los pacientes que han recibido la cirugía y raro entre los que reciben medicamentos bloqueadores alfa. Lo que sucede con la eyaculación inversa es que, durante el clímax sexual, el semen fluye inversamente hacia la vejiga en vez de salir a través del pene.

Los hombres que tienen este problema probablemente no podrán concebir hijos; pero no les afecta en su capacidad de tener una erección y lograr satisfacción sexual, y no ocasiona otros problemas. Probablemente deseará hablar más sobre este tema con su médico.

La eyaculación inversa se presenta entre 40 a 70 pacientes de cada 100 que reciben la cirugía. Entre 7 de cada 100 pacientes que reciben los bloqueadores alfa también se presenta el problema. Los pacientes sólo bajo observación médica y los que toman el finasteride no presentan el problema; a pesar de que algunos de los que toman el medicamento notan que producen menos semen de lo normal.

Considere cuidadosamente todos los beneficios y posibles problemas de cada uno de los tratamientos.

La tabla en las páginas 24 y 25 presenta los beneficios y posibles riesgos de cada tratamiento. Puede usar esta tabla para comparar los tratamientos. Por ejemplo, tanto los pacientes que reciben los bloqueadores alfa como los que reciben la cirugía de resección tienen problemas, pero algunos de éstos son leves y otros son serios, la tabla le ayudará a compararlos.

## ¿Cuál es el siguiente paso?

Antes de elegir un tratamiento, dígale a su médico las siguientes dos preguntas importantes:

1. Si mi inflamación benigna de la próstata no me ocasiona problemas serios, ¿necesito algún otro tratamiento en vez de sólo recibir una cuidadosa observación médica?
2. Si quiero recibir tratamiento ¿cuál es el mejor en mi caso, tomando en cuenta los posibles beneficios y riesgos?

No importa lo que decida, consúltelo con su médico. Puede llevar esta publicación con usted para que le ayude. Dígale todas sus preguntas y, junto con él, tome su decisión final.

## Otros recursos disponibles

Las siguientes organizaciones nacionales le pueden dar más información sobre la condición y sus tratamientos.

- Prostate Health Council
- American Foundation for Urologic Disease, Inc.
- 300 West Pratt Street
- Baltimore, MD 21201
- (teléfono gratis) (800) 242-2383

- National Kidney and Urologic Diseases Information Clearinghouse
- Box NKUDIC
- Bethesda, MD 20892
- (301) 468-6345

## Para obtener más información

La información en esta publicación se obtuvo de la Benign Prostatic Hyperplasia: Diagnosis and Treatment. Clinical Practice Guideline. La guía fue desarrollada por un panel de expertos patrocinados por la Agency for Health Care Policy and Research (AHCPR), una agencia del Servicio de Salud Pública de los estados Unidos. Existen y se están desarrollando otras guías para pacientes en inglés y en español sobre diversos problemas de la salud.

Para más información sobre las guías o para recibir más copias de esta publicación, llame gratis al (800) 358-9295, o escriba a:

- AHCPR Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907

## Tabla de comparación: resultados de tratamientos

Beneficio o riesgo | Sólo observación médica | Bloqueadores alfa | Finasteride | Dilatación con globo | Cirugía de resección transuteral
Probabilidad de mejoría en los síntomas | 31-55% | 59-86% | 54-78% | 37-76% | 75-96%
Grado de mejoría | Desconocido, probablemente menor que con los otros tratamientos | 51% | 31% | 51% | 85%
Probabilidad de complicaciones o daño después de la cirugía | - | - | - | 2-10% (incluye complicaciones durante la dilatación -- sangrado, infección e incapacidad de orinar temporal) | 5-31% (incluye complicaciones durante la cirugía -- sangrado, infección e incapacidad de orinar temporal)
Probabilidad de complicaciones o daño de los tratamientos sin cirugía | 1-5% (problemas por el avance de la condición) | 3-43% (incluyendo mareo, cansancio y baja presión sanguínea) | 14-19% (la mayoría son problemas sexuales) | -- | --
Probabilidad de morir dentro de los 3 primeros meses después del tratamiento | Probablemente no hay mayor riesgo. La probabilidad de morir para los hombres de 67 años es de 8 en cada 1,000 en un período de 3 meses. | Desconocida, probablemente menor que la de la resección transuteral | 0.5-3.3%
Probabilidad de incontinencia urinara como resultado del tratamiento | 0 | 0 | 0 | Ningún reporte | 0.7-1.4%
Probabilidad de sufrir impotencia sexual (no tener erección) como resultado del tratamiento | Aproximadamente 2% (1/50) de los hombres de 67 años sufren de impotencia cada año. No existe información a largo plazo sobre los efectos de los bloqueadores alfa. | 2.5-5.3% | Desconocida, pero probablemente poco común | 3-35% (poco común entre los hombres con funcionamiento completamente normal antes de la cirugía)
Número de días de incapacidad durante el primer año del tratamiento | 1 | 3.5 | 2 | 4 | 7-21