# Anemia de célula falciforme en los recién nacidos y los bebés Guía para los padres

## ¿Qué es la anemia de célula falciforme?

La anemia de célula falciforme (o de célula en forma de hoz) es un desorden hederitario de los glóbulos (o células) rojos de la sangre. Los glóbulos rojos usan una proteína llamada hemoglobina para llevar el oxígeno a todas las partes del cuerpo. Cómo puede ver en el dibujo, los glóbulos rojos normales contienen sólo hemoglobina normal y tienen la forma de un anillo (rosca). Estos glóbulos son muy flexibles y se transportan fácilmente a través de las venas (pequeños vasos sanguíneos).

El dibujo de abajo muestra la célula de la anemia falciforme. Los glóbulos rojos contienen hemoglobina falciforme. Debido a esto, el glóbulo cambia de su forma de anillo a una forma de curva (hoz) déspues de que ha llevado el oxígeno. Los glóbulos falciformes se atoran y forman tapones en los pequeños vasos sanguíneos. Estos tapones en el flujo de la sangre pueden causar daño a los tejidos. Dado que existen vasos sanguíneos en todo el cuerpo, el daño a los tejidos puede ocurrir en cualquier parte.

Los siguientes son los tipos más comunes de anemia de célula falciforme:

- Anemia de célula falciforme.
- Enfermedad de célula falciforme C.
- Enfermedad de célula falciforme beta-talasanemia.

## El propósito de esta publicación

Esta publicación le puede ayudar a entender la anemia de célula falciforme y cómo puede afectar a su bebé.

La mejor manera en la que puede ayudar a su bebé es aprendiendo todo lo posible sobre la enfermedad, los problemas que causa, y lo que puede hacer por su niño. Hable sobre la información en esta publicación y sobre las opciones de tratamiento con el médico y otros profesionales de salud que conocen de la anemia de célula falciforme. Cooperando con ellos le podrá dar el mejor cuidado posible a su bebé.

En la página 2 de esta publicación encontrará descripciones de los problemas que pueden presentarse en un bebé que padece de anemia de célula falciforme. Recuerde al leer estas descripciones que no necesariamente todos los bebés presentarán todos estos problemas. Al final de la publicación encontrará una lista de términos que frecuentemente usan los médicos y las enfermeras cuando hablan sobre la anemia de célula falciforme.

## Tipos de anemia de célula falciforme

Como ya se ha indicado, existen varias formas de esta enfermedad. La más común es la anemia de célula falciforme. El médico le dirá el tipo de anemia de célula falciforme que padece su bebé. Es muy importante que usted escriba el nombre exacto del tipo de anemia de su hijo, de tal manera que lo tenga consigo en caso que le lleve a un médico o a una clínica diferente.

## ¿Cómo afecta la anemia de célula falciforme a los bebés?

Los bebés que padecen de esta enfermedad pueden tener:

- Anemia (un número bajo de glóbulos rojos). La gente que padece anemia se cansa fácilmente.
- Crisis aplástica. Los bebés que padecen anemia de célula falciforme pueden dejar de producir glóbulos rojos por un período de tiempo. Los sintomás son palidez, menos actividad de lo normal, respiración acelerada, y latidos acelerados del corazón. Si el bebé presenta estos sintomás llévelo al médico dé inmediato.
- Síndrome de las manos y los pies. Los niñnos que padecen de anemia de célula falciforme pueden tener dolor e inflamación de las manos o los pies.
- Dolor agudo (intenso) (principalmente en los brazos, manos, piernas, pies, o abdomen). Esto sucede cuando las células falciformes bloquean los vasos sanguíneos impidiendo la circulación dé la sangre. Los médicos se refieren a esta condición como un episodio de dolor.
- Infecciones agudas. El niño que padece de anemia de célula falciforme tiene un alto riesgo de sufrir de infecciones, tales como sepsis (una infección del sistema sanguíneo), meningitis y pulmonía. El riesgo de infección aumenta debido a que el bazo no filtra la sangre correctamente.
- Inflamación del bazo (esplenectasia). El bazo es el órgano del cuerpo encargado de filtrar la sangre. En las personas que padecen de anemia de célula falciforme, el bazo se inflama rápidamente debido al bloqueo de los vasos sanguíneos. Esta condición se conoce como esplenectasía y puede ser muy peligrosa.
- Derrame cerebral.Esto sucede cuando las células falciformes bloquean los vasos sanguíneos del cerebro. Los sintomás incluyen convulsiones, debilidad de los brazos y las piernas, problemas del habla, y perder el conocimiento. Una persona con cualquiera de estos sintomás debe ver al médico de inmediato.

## ¿Quiénes sufren de anemia de célula falciforme?

En los Estados Unidos, la mayoría de las personas que padecen la enfermedad son de raza negra. Aproximadamente 1 de cada 375 niños de raza negra padece de anemia de célula falciforme. Los hispanos procedentes del Caribe, América Central y partes de América del Sur también pueden padecer de esta enfermedad.

## ¿Qué causa la enfermedad?

Todas las formas de la anemia de célula falciforme son hederitarias. Es decir, que los padres le pasan esta enfermedad a sus hijos.

Los genes determinan todas las características de cada bebé, como el color de los ojos o la estatura. Los genes son una sustancia que se encuentra en el esperma del padre y el óvulo o huevo de la madre. Los niños heredan los genes de la hemoglobina de sus padres. Las personas que heredan tanto la hemoglobina normal como la falciforme, tienen el "rasgo genético de anemia de célula falciforme. " Tener el rasgo genético de anemia de célula falciforme no es una enfermedad y nunca se convierte en la enfermedad. Sin embargo, una persona con este rasgo genético puede pasarle a sus hijos hemoglobina normal, o hemoglobina falciforme. Este es un proceso complejo, si no lo entiende, hable con su médico o enfermera.

Si el padre y la madre tienen el rasgo de célula falciforme, para cada embarazo, tienen las siguientes probabilidades de pasarle esta característica a sus hijos (vea la ilustración en la siguiente hoja):

- 1 probabilidad de 4 que el bebé tendrá hemoglobina normal.
- 2 probabilidades de 4 que el bebé tendrá tanto hemoglobina normal como hemoglobina de célula falciforme (o rasgo genético de anemia de célula falciforme).
- 1 probabilidad de 4 que el bebé sólo tendrá hemoglobina de célula falciforme (es decir, que padezca de anemia de célula falciforme).

## ¿Cómo puedo saber si mi bebé padece dé anemia de célula falciforme?

Para detectar la anemia de célula falciforme se tiene que hacer un examen médico de la sangre a todos los recién nacidos. Muchos hospitales tienen programas de detección en los cuales se hace el examen médico a todos los niños a los pocos días de nacidos. Para hacer el examen, se toma una muestra de sangre del talón del niño, y así detectar la anemia de célula falciforme y otros problemas de salud.

Si los resultados del examen muestran que su bebé podría tener la enfermedad, se vuelve a realizar el examen para asegurarse del diagnóstico. El médico pedirá una muestra de sangre de uno o ambos padres y le dirá lo más pronto posible si su niño padece de la enfermedad.

## ¿Qué sucede si el bebé padece de anemia de célula falciforme?

Si su bebé padece de la enfermedad, el médico le ayudará a encontrar el mejor cuidado disponible. Los siguientes profesionales se podrían encargar del cuidado del paciente: Un médico de familia, un pediatra (especializado en niños), un hematólogo pediátrico (médico especializado en enfermedades de la sangre en niños), o le darán cuidado en una clínica especializada en el tratamiento de anemia de célula falciforme. Probablemente usted también déseara visitar a un consejero para conversar sobre las probabilidades que tiene de tener otro bebé que padezca de la misma enfermedad.

La anemia de célula falciforme no es sólo un problema médico. Probablemente también tendrá preocupaciones en cuanto a su bebé y su familia, cómo controlar los problemas emocionales y cómo poder pagar las cuentas médicas. Su médico o enfermera puede hablarle sobre estas preocupaciones. Ellos también le pueden ayudar a encontrar una agencia de servicios sociales a nivel local para que le den ayuda. En muchas ciudades existen grupos de apoyo para la anemia de célula falciforme. También existen organizaciones comunitarias que ofrecen los exámenes médicos de detección, y educación y apoyo para las familias que tienen niños que padecen la enfermedad o el rasgo genético de la enfermedad. (Pregunte al médico o la enfermera si existen grupos o servicios en español).

## ¿Cómo puedo ayudar a mi bebé?

La mejor manera de ayudar a su bebé es aprender lo más que pueda sobre la enfermedad y tratar de asegurarse que reciba el mejor cuidado disponible. El niño que padece de anemia de célula falciforme tiene necesidades específicas y debe recibir cuidado regularmente para mantenerle lo más sano posible. El médico le explicará la frecuencia con la que tiene que proporcionarse el cuidado y lo que puede hacer en caso que el niño se enferme.

A los 2 meses de edad, su bebé empezará a tomar penicilina en forma oral (por la boca) dos veces al día. Es muy importante que le dé la penicilina exactamente cómo lo indique el médico. El médicamento ayudará a prevenir infecciones. El niño deberá usar penicilina por lo menos hasta que cumpla los 5 años de edad.

También a los 2 meses, el niño recibirá una inyección para protegerlo de la Influenza H, que es una bacteria que causa una infección que es peligrosa para las personas que padecen de anemia de célula falciforme. El bebé también necesitará una inyección para protegerlo de la hepatitis B, una enfermedad del hígado. Además, deberá recibir todas las demás vacunas que reciben todos los niños. Hable sobre esto con el médico.

A continuación se presenta una lista de las cosas importantes que debe saber si sus niño padece de anemia de célula falciforme:

- Si el niño presenta una fiebre (más alta de los 101 grados), debe obtener ayuda médica de inmediato. Una fiebre en un niño que padece la enfermedad puede ser un síntoma de un problema médico grave. Cuando su niño parezca enfermo, siempre debe tomarle la temperatura. Su médico le dirá qué hacer si el niño tiene fiebre.
- Si cualquier médico o enfermera nuevo ve a su bebé por cualquier motivo, tiene que explicarle que padece de anemia de célula falciforme.
- Una buena alimentación es muy importante para todos los bebés. Pregunte a su médico sobre los mejores alimentos y líquidos para darle al bebé. Trate que beba muchos líquidos. También pregunte si es necesario que tome vitaminas o suplementos de hierro.
- Asegúrese que su bebé no sienta demasiado calor o demasiado frío. Manténgalo templado. Los baños fríos o el aire frío puede reducir la velocidad del flujo de la sangre y esto puede ocasionar problemas.

Si el niño se enferma, debe recibir atención médica inmediata. Cualquier síntoma de enfermedad que presente un niño con anemia de célula falciforme puede ser grave. Si su bebé tiene cualquiera de los siguientes sintomás, debe llevarlo al médico dé inmediato:

- Tiene la respiración acelerada, o tiene problemas para respirar.
- Tos frecuente.
- Está de mal humor y llora más dé lo normal.
- Grita cuando se le toca.
- Está muy cansado, o tiene poca energía.
- Está muy débil.
- Vomita.
- No quiere comer.
- Tiene diarrea.
- No moja el mismo número dé pañales (orina menos de lo normal).
- Tiene dolor o hinchazón del abdomen (vientre).
- Tiene las manos o los pies hinchados.
- Tiene los labios y la piel de un color azuloso o grisáceo.

## Las preguntas que probablemente déseara hacer

Haga cualquier pregunta que tenga sobre la enfermedad y la manera en la que afecta a su familia. A continuación hay una serie de preguntas que probablemente le déseara hacer a su médico, enfermera, consejero, o trabajador social. Al final de la lista se proporciona espacio para que escriba más preguntas.

- ¿Qué tiene mi bebé? ¿Cómo es que le dio esta enfermedad?
- ¿Cómo le pasé la enfermedad a mi bebé? ¿Cómo es que tengo este rasgo genético? ¿Cómo va a afectar a mi familia?
- ¿Con qué frecuencia necesito traerle a mi bebé?
- ¿Qué medicamento tiene que tomar mi bebé¿Qué necesito saber sobre el medicamento para dárselo a mi bebé?
- ¿Qué le debo de dar de comer y beber a mi bebé?
- ¿Cuáles actividades no debe hacer mi bebé?
- ¿Cómo me puedo dar cuenta si se enferma mi bebé?
- ¿Qué debo hacer, y a quién debo llamar si se enferma mi bebé?
- ¿Qué otro tipo de ayuda está disponible para mi familia?

## Para obtener más información

Para aprender más sobre la anemia de célula falciforme y cómo tolerar está enfermedad puede solicitar ayuda de (pregunte si cuentan con asistencia y publicaciones en español):

- National Association for Sickle Cell Disease
- 3345 Wilshire Boulevard
- Suite 1106
- Los Angeles, CA 90010-1880
- 1-800-421-8453

Otras fuentes de información

- California State Department of Health
- Childrens Medical Services Branch
- Sacramento, CA 95814
- 916-654-0499

- Cincinnati Comprehensive Sickle Cell Center
- Children's Hospital Medical Center
- Cincinnati, OH 45229
- 513-559-4200

- Clinical Center Communications
- 9000 Rockville Pike
- Building 10, Room 1C255
- Bethesda, MD 20892
- 301-496-2563

- Education Programs Associates
- 1 West Campbell Ave, Building D
- Campbell, CA 95008
- 408-374-1210

- Howard University
- Comprehensive Sickle Cell Center
- 2121 Georgia Ave
- Washington DC 20059
- 202-806-7930

- March of Dimes
- Birth Defects Foundation
- 1275 Mamaroneck Avenue
- White Plains, NY 10605

(Para obtener servicio más rápido, busque el teléfono local de "March of Dimes" en su directorio telefónico)

- Mid-South Sickle Cell Center
- Le Bonheur Children's Medical Center
- Memphis, TN 38103
- 901-522-6792

- Mississippi State Department of Health
- Genetics Division
- PO Box 1700
- Jackson, MS 39215
- 601-960-7619

- National Maternal and Child Health Clearinghouse
- 8201 Greensboro Drive
- Suite 600
- McLean, VA 22102
- 703-821-8955

- New York State Department of Health
- Newborn Screening Program
- Wadsworth Center for Laboratories and Research
- P.O. Box 509
- Albany, NY 12201-0509
- 518-473-7552

- Northern California Comprehensive Sickle Cell Center
- San Francisco, CA 94110
- 510-428-3651

- Texas Department of Health
- Newborn Screening Program
- 1100 West 49th St
- Austin, TX 78756-3199
- 512-458-7111

Esta no es una lista completa. Consulte con el departamento de salud de su estado o localidad, o con la agencia de anemia de célula falciforme para obtener otras fuentes de información.

## Palabras comunes que se usan con referencia a la anemia de celula falciforme

Su médico o enfermera puedé usar las siguientes palabras cuando hable sobre la anemia de célula falciforme.

- Anemia. Un número reducido de glóbulos rojos en la sangre. Esto les sucede a las personas que padecen la enfermedad porque las células falciformes de la sangre viven menos tiempo que las células normales. El cuerpo no puede producir las suficientes células (glóbulos) rojas falciformes para poder reemplazar las que se pierden, así es que la persona tiene menos glóbulos rojos de lo normal y está anémica.

- Anemia de célula falciforme. Un grupo de desordénes heredados en los cuales se presenta anemia y el cuerpo produce hemoglobina en forma de hoz (falciforme).

- Anemia de célula falciforme. Es el tipo más común de la enfermedad. Los otros tipos incluyen la enfermedad de célula falciforme C y la enfermedad de célula falciforme beta-talasanemia. También existen otros tipos de esta enfermedad, pero estos son menos comunes.

- Capilares. Pequeñísimos vasos sanguíneos (venas) en donde las células falciformes se quédan atrapadas causando problemas.

- Células falciformes (en forma de hoz). En las personas que padecen de la enfermedad, las moléculas de hemoglobina de los glóbulos rojos se pegan unas a otras haciendo que los glóbulos rojos cambien de su forma de anillo a una similar a la de una hoz. Estas células defectuosas no pueden pasar a través de los pequeñísimos vasos sanguíneos (venas).

- Crisis aplástica. Esto sucede cuando la médula espinal del niño deja de producir glóbulos rojos temporalmente. Un niño con una crisis aplástica puede aparecer pálido, cansado y menos activo de lo normal.

- Episodio de dolor. Las personas que padecen de anemia de célula falciforme pueden sentir dolor debido al bloqueo de los vasos sanguíneos. Con frecuencia, el dolor se presenta en los brazos, las piernas, la espalda y el abdomen. El dolor puedé durar unas cuantas horas o hasta una o dos semanas. El dolor puede ser leve o severo y puede ser necesario utilizar medicamentos. El número de episodios de dolor varía significativamente de un individuo a otro.

- Esplenectasia (inflamación del bazo). Esto sucede cuando una gran cantidad de la sangre del niño se queda atrapada en el bazo. Los sintomás tempranos incluyen palidez, hinchazón del bazo, y dolor en el abdomen (vientre).

- Gene. La unidad biológica a través de la cual se heredan características de ambos padres. Los genes determinan todas las características del niño. Por ejemplo, el pelo, los ojos, y el color de la piel, el tamaño de los pies, y la estatura. También determinan si el niño padecerá de anemia de célula falciforme o alguna otra enfermedad hederitaria.

- Hemoglobina. Una molécula que se encuentra en los glóbulos rojos y que transporta el oxígeno desde los pulmones a todas las partes del cuerpo.

- Influenza Haemophylus. Un tipo de bacteria que causa una infección que puede provocar problemas graves en un niño que padece de anemia de célula falciforme. El bebé debe recibir una vacuna especial a los 2 meses de edad para protegerle contra esta influenza.

- Rasgo genético de célula falciforme. Es una condición en la que la persona tiene hemoglobina normal y hemoglobina en forma de hoz (falciforme). Esto sucede porque la persona heredó un gene de hemoglobina normal y uno falciforme de sus padres. El rasgo genético de anemia de célula falciforme no es una enfermedad y la persona nunca padecerá la enfermedad. Sin embargo, una persona con este rasgo genético se lo puede pasar a sus hijos.

- Sepsis. Es una infección del sistema sanguíneo.

- Síndrome agudo de pecho. Esta es una condición grave causada por una infección o por glóbulos rojos que se han quedado atrapados en los pulmones. Los síntomas de este síndrome en el niño que padece de anemia de célula falciforme son dificultad para respirar, dolor de pecho y tos. Normalmente un niño con este problema deberá internarse en un hospital para recibir tratamiento.

- Síndrome de manos y pies. Es el dolor de las manos y los pies provocado por las células falciformes que se quedan atrapadas en los vasos sanguíneos (venas). Frecuentemente este es el primer problema que se presenta en un niño que padece de anemia de célula falciforme.

- Streptococcus pneumoniae. Una bacteria que causa un tipo de pulmonía grave en los niños que padecen de anemia de célula falciforme. Dos dosis diarias de penicilina desde los dos meses de edad permiten prevenir este tipo de enfermedad mortal en los niños con anemia de célula falciforme y anemia beta-talasanemia.

## Para mayor información

La información en esta publicación se tomó de la Clinical Practice Guideline on Sickle Cell Disease: Screening, Diagnosis, Management, and Counseling in Newborns and Infants (Guía de práctica clínica sobre la anemia de célula falciforme: Detección, diagnóstico, control, y consejería para familias de recién nacidos y bebés que padecen la enfermedad). La Guía fue escrita por un panel de expertos patrocinados por la Agency for Health Care Policy and Research. Ahora existen y se están desarrollando otras Guías sobre problemas comunes de salud tanto en inglés como en español.

Para más información sobre las Guías, o para solicitar más copias de esta publicación, diríjase a:

- Agency for Health Care Policy and Research
- Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907

O llame al 1-800-358-9295 (para llamadas procedentes de fuera de los Estados Unidos, llame al 301-495-3453) durante los días de la semana de las 9 a.m. a las 5 p.m. hora de la costa este.