# Existen tratamientos para la depresión

## Para encontrar ayuda

La depresión es una enfermedad seria, pero existen profesionales de la salud que la pueden tratar exitosamente. Si usted cree que padece de depresión, hay varios lugares en donde puede recibir la ayuda que necesita. Usted puede:

- Llamar a su médico de familia o a un profesional de la salud.
- Llamar al departamento de salud en su localidad, la clínica de salud mental de la comunidad, el hospital, o una clínica. En estos lugares le pueden ayudar, o le pueden decir a dónde ir para recibir ayuda.
- Llamar a la facultad de medicina de una universidad local (muchas de ellas cuentan con programas especiales para el tratamiento de la depresión).
- Llamar a una de las organizaciones nacionales que se presetan a continuación. Ellos pueden darle información sobre profesionales de la salud en su localidad. También le pueden dar más información sobre la depresión, enviarle libros y folletos sobre este tema, y darle información sobre grupos de apoyo.

- National Alliance for the Mentally Ill (NAMI)
- (Alianza Nacional para los Enfermos Mentales)
- 2101 Wilson Blvd, Suite 302
- Arlington, VA 22201
- Teléfono gratuito: 800-950-6264

- National Depressive and Manic Depressive Association (NDMDA)
- (Asciación Nacional de Depresíon y Trastorno Maniaco Depresivo)
- 730 N. Frañklin St., Suite 501
- Chicago, IL 60610
- Teléfono gratuito: 800-82-NDMDA

- National Foundation for Depressive Illness, Inc. (NFDI) (Fundación
- Nacional de Enfermedades Depresivas)
- P.O. Box 2257
- New York, NY 10116-2257
- Teléfono gratuito: 800-248-4344

- National Mental Health Association (NMHA)
- National Mental Health Information Center (Asociación
- Nacional de Salud Mental,
- Centro Nacional de Información sobre la Salud Mental)
- 1021 Prince Street
- Alexandria, VA 23314-2971
- Teléfono gratuito: 800-969-6642

## El propósito de esta publicación

Esta publicación trata sobre el trastorno depresive mayor, que es sólo uno de los tipos de enfermedades depresivas. Si usted no está seguro de que padece de este tipo de depresión, está publicación le puede ayudar a responder a sus preguntas y darle más información.

Esta publicación tiene dos secciones:

- Sección 1: que responde a las preguntas más comunes sobre la depresión y proporciona información básca.
- Sección 2: que proporciona información más detallada sobre la depresión y los tratamientos. La publicación también le proporciona espacio para que pueda escribir notas y otra información importante.

Esta publicación es suya. La puede usar de cualquier manera que le sea útil. Probablemente usted deseará:

- Llevarla consigo cuando visite a su médico. Las notas escritas y su información le ayudarán a recibir el mejor tratamiento posible.
- Dejar que sus familiares o amigos la lean. Esto probablemente les ayudará a entender mejor su enfermedad depresiva y los tratamientos.

La información que se proporciona en esta publicación está basada en los resultados de estudios de evaluación de investigación científica. Existen otros tratamientos para la depresión que, a pesar de que son eficaces para ciertos pacientes, no se han estudiado cuidadosamente en una forma científica.

En esta publicación, la palabra depresión describe el trastorno depresive mayor.

## Sección 1

### Lo que usted debe saber

#### ¿Quiénes se deprimen?

El trastorno depresive mayor -frecuentemente llamado simplemente depresión- es una enfermedad común que puede afectar a cualquier persona. Aproximadamente 1 de cada 20 personas en los Estados Unidos padece de depresión cada año (más de 11 millones de personas). La depresión afecta a un número doble de mujeres que de hombres.

#### ¿Qué es la depresión?

La depresión no es solamente un sentimiento de "tristeza" o de " estar recaído de ánimo." Es algo más que el sentirse triste o el sentimiento de tristeza después de haber perdido a un ser querido. La depresión es una enfermedad (igual que la diabetes, la presión arterial alta, o las enfermedades del corazón) que día tras día afecta sus pensamientos, sentimientos, salud física, y su forma de comportarse.

La depresión puede ser el resultado de muchas razones:

- La herencia genética (que corre en su familia).
- Otras enfermedades.
- Ciertos medicamentos.
- El uso de drogas o alcohol.
- Otros problemas mentales (psiquiátricos).

Ciertas situaciones de la vida (como muy alta tensión emocional, o el dolor por la muerte o pérdida de un ser querido), pueden desencadenar la depresión o provocar que el paciente no se pueda recuperar completamente. En algunas personas la depresión se presenta incluso cuando todo en sus vidas marcha bien.

La depresión no es la culpa de la persona que la padece. No es una debilidad de la personalidad. Es una enfermedad médica. La depresión es una enfermedad para la que existen tratamientos.

#### ¿Cómo puedo saber si padezco de depresión?

Las personas que padecen de depresión tienen ciertos síntomas que les afectan casi todos los días, el día entero, por lo menos por un período de dos semanas. Estos síntomas casi siempre incluyen por lo menos uno de los siguientes:

- Perder interés en las cosas que antes disfrutaba.
- Sentirse triste, decaído emocionalmente o cabizbajo.

Probablemente tendrá por lo menos tres de los siguientes síntomas:

- Sentir que no tiene energía, o al contrario, sentirse inquieto y sin poder quedarse tranquilo.
- Sentir como que no vale nada o sentirse culpable.
- Que le aumente o disminuya el apetito o el peso.
- Tener pensamientos sobre la muerte o el suicidio.
- Tener problemas para concentrarse, pensar, recordar, o tomar decisiones.
- No poder dormir, o dormir demasiado. Perder su energía o sentirse cansado todo el tiempo.

Frecuentemente la depresión también tiene otros síntomas de tipo físico o psicológico, estos incluyen:

- Dolores de cabeza.
- Dolores y sentirse adolorido de otras partes del cuerpo.
- Problemas digestivos (del estómago).
- Problemas sexuales.
- Sentirse pesimista o desesperanzado.
- Sentirse ansioso o preocupado.

#### ¿Qué debo hacer si tengo estos síntomas?

Frecuentemente, las personas no buscan ayuda para tratar la depresión porque no reconocen los síntomas, no saben cómo pedir ayuda, se culpan a sí mismas por los síntomas, o simplemente no saben que existen tratamientos para la enfermedad.

Los pacientes recurren primero al médico de familia, las clínicas, o las organizaciones de servicios de salud (en inglés "HMO"). Por lo general lo que sucede entonces es que:

- Se tratará de determinar si existe una razón física que provoque la depresión.
- Se proporcionará tratamiento contra la depresión.
- Se recomendará al paciente a un especialista de salud mental para que se realicen más evaluaciónes y tratamientos.

Si usted no cuenta con un médico de familia, llame al departamento de salud de su localidad, o la clínica local de salud mental, o un hospital. Las facultades de medicina también tienen centros que proporcionan tratamiento para la depresión.

#### ¿De qué manera me ayudará el tratamiento?

El tratamiento contra la depresión ayuda a reducir el dolor y sufrimiento de enfermedad. El tratamiento eficaz quita todos los síntomas de la depresión y permite que usted reanude su vida normal. Mientras más pronto reciba el tratamiento, más pronto se empezará a sentir mejor. De igual manera que con otras enfermedades, mientras más tiempo tenga la depresión sin recibir tratamiento, más difícil será proporcionarle tratamiento eficaz.

En la contraportada de esta publicación hay una lista de organizaciones en donde le pueden proporcionar ayuda e información.

La mayoría de las personas que reciben tratamiento contra la depresión se sienten mejor y pueden volver a realizar sus actividades cotidianas después de algunas semanas. Debido a que el efecto total del tratamiento tarda unas cuantas semanas, es muy importante que se lo den lo más pronto posible y antes de que la enfermedad empeore.

Como es el caso con muchas enfermedades, probablemente será necesario que le den uno o dos diferentes tratamientos antes de encontrar el que es mejor en su caso. Es importante no desanimarse si el primer tratamiento no funciona. En casi todos los casos, existirá un tratamiento que será eficaz.

#### ¿Qué tipo de tratamiento recibiré?

Los principales tratamientos contra la depresión son los siguientes:

- Los medicamentos antidepresives.
- La psicoterapia (hablar con un médico o terapeuta especializado en problemas Una combinación de los medicamentos antidepresives y la psicoterapia.

Para algunos casos de depresión, existen otros tratamientos eficaces como la terapia electroconvulsiva y la terapia de luz.

Tener pensamientos sobre la muerte o el suicidio es frecuentemente uno de los síntomas de la depresión. Si usted tiene estos pensamientos, hable con alguien en quien confíe ahora mismo. Pídale que le ayude a encontrar servicios profesionales de inmediato. Usted dejara de tener estos pensamientos una vez que se le hayan dado un tratamiento adecuado para la depresión.

#### ¿Quiénes deben visitar a un profesional de salud mental?

Muchas personas que sufren de depresión pueden recibir tratamiento adecuado en manos de su médico familiar. Sin embargo, algunas personas necesitarán tratamiento especializado si: El primer tratamiento que se les dio no fue eficaz; o si necesitan una combinación de tratamientos; o si la depresión es demasiado severa, o ha durado por demasiado tiempo. En muchas ocasiones lo único que es necesario es una consulta de segunda opinión. Si el especialista de salud mental proporciona el tratamiento, en la mayoría de las ocasiones es como paciente de consulta externa (es decir, fuera del hospital). Si usted piensa que necesita consultar a un especialista de salud mental, dígaselo a su médico, o llame a una de las organizaciones que se presetan en la contraportada de esta publicación. También le presentaremos más información sobre los tipos de profesionales que pueden tratar la depresión a continuación en la página 7.

La sección 2 de esta publicación le dirá más sobre la depresión, su diagnóstico y tratamiento.

#### Los especialistas que tratan la depresión

Los siguientes especialistas de la salud proporcionan tratamiento contra la depresión.

- Médicos generales o de familia.
  - Médico -- Un profesional de salud que tiene alguna capacitación en proporcionar tratamiento médico para enfermedades mentales o psiquiátricas.
  - Asistente médico -- Un individuo con capacitación médica y alguna capacitación en el tratamiento de enfermedades mentales o psiquiátricas.
  - Enfermera -- Una enfermera certificada con capacitación médica adicional en el tratamiento de enfermedades mentales o psiquiátricas.

Cualquiera de los especialistas de salud que acabamos de mencionar le puede dar una referencia para consultar a uno de los especialistas en el tratamiento de enfermedades mentales que se presetan a continuación.

- profesionales de la salud mental.
  - Psiquiatra -- Un médico que se especializa en el diagnóstico y tratamiento de las enfermedades mentales o psiquiátricas.
  - Psicólogo -- Una persona con un doctorado en psicología y capacitación en consultoría, psicoterapia, y pruebas psicológicas de evaluación.
  - Trabajador social -- Una persona con una licenciatura en trabajo social. Un trabajador social con una maestría, frecuentemente cuenta con la capacitación para dar consejería.
  - Enfermera psiquiátrica -- Una enfermera certificada y con una maestría en la práctica de enfermería psiquiátrica que se especializa en el tratamiento de enfermedades mentales o psiquiátricas.

Nota: Cuando se usa el término de profesional de la salud (o médico) en esta publicación, se refiere a cualquiera de los profesionales generales o especializados en el área de la salud mental que se mencionaron anteriormente.

## Sección 2

### Síntomas de la depresión

Cuando una persona está deprimida, tiene varios síntomas casi todos los días, durante todo el día, y éstos duran por lo menos dos semanas.

Puede usar la lista a continuación para marcar los síntomas que ha tenido por dos semanas o más.

- [ ] Perder interés en las cosas que antes disfrutaba, incluyendo las relaciones sexuales.*
- [ ] Sentirse triste, decaido emocionalmente o cabizbajo. *
- [ ] Sentir que no tiene energía, o al contrario, sentirse inquieto y sin poder quedarse tranquilo.
- [ ] Sentir como que no vale nada o sentirse culpable.
- [ ] que le aumente o disminuya el apetito o el peso.
- [ ] Tener pensamientos sobre la muerte o el suicidio; intentos de suicidio.
- [ ] Tener problemas para concentrarse, pensar, recordar, o tomar decisiones.
- [ ] No poder dormir, o dormir demasiado.
- [ ] Perder su energía o sentirse cansado todo el tiempo.

Otros síntomas incluyen:

- [ ] Dolores de cabeza.
- [ ] Dolores y sentirse adolorido de otras partes del cuerpo.
- [ ] problemas digestivos (del estómago).
- [ ] problemas sexuales.
- [ ] Sentirse pesimista o desesperanzado.
- [ ] Sentirse ansioso o preocupado.

Si ha tenido cinco o más de los síntomas anteriores incluyendo por lo menos uno de los dos marcados con un asterisco (*) en las últimas dos semanas, puede ser que padezca de un trastorno depresive mayor. visite a su médico para que le hagan un diagnóstico.

También le debe decir a su médico si tiene algunos de los otros síntomas de la depresión. Algunas veces, unos cuantos síntomas pueden prolongarse y convertirse en un trastorno depresive mayor. Algunas formas de la depresión son menos severas, pero pueden ser persistentes o crónicas. Es necesario dar tratamiento para los síntomas crónicos de la depresión.

#### Otro tipo de depresión

Algunas personas que padecen de depresión tienen cambios cíclicos de humor. Es decir que tienen períodos marcados "de tristeza" (depresión) y períodos de inadecuada " actividad o alegría " (manía) que pueden durar desde varios días, hasta varios meses. En los intervalos entre la tristeza y la actividad o alegría, la persona se siente totalmente normal. Esta condición es conocida como trastorno bipolar maniaco depresive.

El trastorno bipolar afecta a aproximadamente una de cada cien personas. De la misma manera que heredamos el color de los ojos o el cabello de nuestros padres, también a veces heredamos el trastorno bipolar. Esta condición también puede resultar de otros problemas médicos como lesiones a la cabeza, condiciones neurológicas, u otros problemas de salud.

Puede usar la siguiente lista para aprender sobre los síntomas de la manía y para marcar los que usted padece.

- [ ] Sentirse demasiado "alegre," eufórico, o irritable. *
- [ ] necesitar menos sueño.
- [ ] Hablar demasiado, o sentir que no puede dejar de hablar.
- [ ] Distraerse fácilmente.
- [ ] Tener muchas ideas, todas al mismo tiempo.
- [ ] Hacer cosas que le hacen sentir bien pero que tienen malos resultados (gastar demasiado dinero, actividad sexual inapropriada, malas inversiones de negocios).
- [ ] Sentir que usted es muy importante.
- [ ] Planear muchas actividades (en el trabajo, la escuela, o sociales), o sentir que tiene que estar en movimiento continuo.

Si ha tenido cuatro de estos síntomas a la vez, por lo menos por una semana, incluyendo el primer síntoma marcado con un asterisco (*), probablemente ha pasado por un episodio maníaco. Dígale a su médico sobre este episodio. Existen tratamientos eficaces para este tipo de depresión.

### Causas de la depresión

Los trastornos depresives mayores no son el resultado de un solo factor. Probablemente son el resultado de una combinación de factores biológicos, genéticos, psicológicos y otros. Ciertas experiencias de la vida (tales como mucha tensión o pesar) pueden desencadenar una tendencia psicológica o biológica natural hacia la depresión. En algunas personas, la depresión sucede incluso cuando sus vidas son estables.

Beber demasiado alcohol o usar drogas a veces puede causar depresión. Normalmente, cuando se dejan de usar el alcohol o las drogas, desaparece la depresión. Hable con su médico si tiene un problema con el consumo de drogas o alcohol; existen tratamientos.

Recuerde que los trastornos depresives mayores no son el resultado de una debilidad de la personalidad, ni pereza, ni falta de fuerza de voluntad. Es una condición médica que se puede tratar.

### El diagnóstico de la depresión

Antes de dar tratamiento contra la depresión, ésta se debe de diagnosticar adecuadamente. Su médico hará lo siguiente:

- Preguntarle sobre los síntomas.
- Preguntarle sobre su salud en general.
- Preguntarle sobre el historial médico de su familia y sobre los problemas de salud mental de su familia.
- Le hará un examen físico.
- Le hará exámenes médicos de laboratorio básicos.

### Información sobre mi salud

Si ha estado marcando esta publicación, en este momento ya tiene información sobre sus síntomas (en la página 8) para que pueda hablar de ellos con su médico. Aquí le damos algunos ejemplos sobre los tipos de preguntas que le hará el médico sobre su salud. Usted puede escribir sus respuestas en el espacio después de las preguntas.

- Enfermedades que tengo o he tenido (por ejemplo, cañcer, artritis, enfermedades del corazón, enfermedades de la tiroides, u otras enfermedades).
- Otros períodos de depresión o de enfermedad mental que he padecido.
- Drogas o alcohol que uso regularmente.
- Medicamentos que estoy tomando ahora o que tomo regularmente; ya sea recetados por un médico, o que compro en la farmacia sin receta.
- Alergias que le tengo a los alimentos, medicinas, u otras cosas.
- Enfermedades que corren en mi familia (como la diabetes, enfermedades del corazón, y otras).
- Antecedentes de enfermedades mentales de mi familia (como el suicidio, trastornos maniaco depresives, hospitalización debida a un trastorno mental, y condiciones neurológicas); o algún pariente que tuvo una "enfermedad inexplicable" o que estuvo internado.
- Los cambios o tensiónes que han sucedido recientemente en mi vida son:

1. - Probablemente deseará escribir más información como:
  - El nombre de un pariente o amigo que podría ayudarme:
  - Teléfono:
  - Otras notas:

#### Como prepararse para su primera visita

Usted le puede ayudar a su médico a diagnosticarlo o tratarlo mejor dándole tanta información como sea posible sobre su salud. Puede usar las preguntas que le presentamos anteriormente para escribir la información. Recuerde que la información que comparte con su médico es totalmente confidencial (no se lo dice a nadie más).

Si la depresión le hace difícil poder hablar o recordar, lleve a un miembro de su familia o a un amigo para que le ayude durañte su primera visita.

Un historial médico general, un examen médico, y exámenes médicos de laboratorio pueden ayudar a determinar si su depresión es el resultado de una condición médica.

Aproximadamente entre el 10 y 15 por ciento de las depresiones son provocadas por una condición médica (como la enfermedad de la tiroides, el cañcer, o enfermedades neurológicas) o por medicamentos. Una vez que se da tratamiento contra la enfermedad, o se ajusta la dosis o el medicamento que está tomando el paciente, la depresión desaparecerá.

Si usted padece de una enfermedad y además se siente deprimido, es importante que se lo diga al médico. A veces la depresión sucede cuando se padece de una enfermedad grave. El obtener ayuda durante momentos difíciles en su vida le puede ayudar a enfrentar las enfermedades.

Si su primer episodio depresive mayor ocurre después de los 40 años de edad, es muy importante que le hagan un cuidadoso examen médico general.

#### La depresión severa, moderada y leve

En la sección sobre los tratamientos contra la depresión se usan los términos depresión severa, moderada y leve. Esto en general quiere decir:

- Depresión severa. cuando la persona presenta casi todos los síntomas de la depresión y la depresión le impide realizar sus actividades de la vida diaria.
- Depresión moderada. cuando la persona presenta muchos de los síntomas de la depresión y éstos le impiden realizar las actividades de la vida diaria.
- Depresión leve. cuando la persona presenta algunos de los síntomas de la depresión y el realizar sus actividades de la vida diaria toma un esfuerzo extraordinario.

Existe un tratamiento adecuado para cada uno de los tipos de depresión. Debe hablar con su médico sobre el tipo de depresión que padece y el tratamiento más adecuado en su caso.

### Tratamientos para la depresión

El tratamiento para la depresión generalmente es de dos pasos.

- Primer paso: Tratamiento intensivo.
- Segundo paso: Continuación del tratamiento.

El propósito del tratamiento intensivo es hacer que los síntomas de la depresión desaparezcan; y lograr que el paciente se sienta bien. La continuación del tratamiento, que quiere decir que el paciente recibe tratamiento incluso después de que se siente bien, es importante porque impide que la depresión regrese. Dependiendo del tipo de tratamiento que se le da al paciente, la probabilidad de que la persona se sienta bien por los primeros 6 meses después del tratamiento de continuación es muy buena.

En los casos en los que la depresión es recurrente (tres o más episodios), se usa un tercer paso de tratamiento, conocido como tratamiento de mantenimiento. Esto quiere decir que el paciente queda en tratamiento por un período más largo. El propósito del tratamiento de mantenimiento es que la depresión no se vuelva a presentar y la probabilidad que la persona se sienta bien es también muy buena.

#### Tipos de tratamiento

Los principales tipos de tratamiento contra la depresión son los siguientes:

- Medicamentos antidepresives.
- Psicoterapia (hablar con un médico o especialista en salud mental).
- Medicamentos antidepresives en combinación con la psicoterapia.
- Otros tratamientos, incluyendo la terapia electroconvulsiva (conocida en inglés con las letras "ECT") y la terapia con el uso de luz.

Los estudios científicos indican que el uso de medicamentos es muy eficaz en el tratamiento de la depresión severa. El uso de la psicoterapia para el tratamiento de la depresión severa no ha sido lo suficientemente investigado.

#### La manera en la que funciona el tratamiento

El tratamiento contra la depresión funciona gradualmente en el transcurso de varias semanas. Con el uso de los medicamentos, los pacientes empiezan a ver buenos resultados en 3 o 4 semanas. cuando se usa solamente la psicoterapia, a veces esto se lleva más tiempo. Hay muy altas probabilidades que el primer tratamiento sea eficaz en su caso, pero si el tratamiento no empieza a dar resultados en cierto período de tiempo, éste se puede cambiar o ajustar. Existen otros tratamientos que se pueden usar, y la probabilidad de encontrar un tratamiento eficaz es muy buena.

#### Elegir un tratamiento

Usted y su médico pueden cooperar para encontrar el mejor tratamiento en su caso. Al elegir un tratamiento intensivo que sea adecuado para usted, debe considerar las posibilidades de mejorarse (beneficios) en contra de las posibles desventajas, los costos del tratamiento, y los costos de padecer de depresión (el dinero que pierde por no trabajar, o el efecto que tiene la depresión en sus relaciones personales, etc.). Las siguientes preguntas probablemente le ayudarán cuando hable con el médico sobre su tratamiento.

1. ¿Cuáles son las probabilidades de mejorarse con este tratamiento?
2. ¿Cuáles son los posibles riesgos y efectos secundarios del tratamiento?
3. ¿Cuál es el costo del tratamiento?

#### La hospitalización

La mayoría de las personas que padecen de depresión reciben su tratamiento como pacientes externos de un médico. Sin embargo, a veces es necesario internar al paciente en un hospital. Esto es debido a que probablemente otras condiciones médicas pueden afectar el tratamiento, o que el paciente necesita cuidado en un hospital (cuando se tiene que ajustar la dosis de medicamentos). Los pacientes que tienen riesgo de cometer suicidio también se tienen que internar hasta que pasen estos sentimientos y el tratamiento empiece a funcionar. Si el paciente tiene que internarse en un hospital, por lo general es sólo por unos días o un máximo de una a dos semanas. Recibir tratamiento en las etapas tempranas de la depresión, antes de que se haga severa o crónica, puede prevenir la necesidad de hospitalizar al paciente.

#### Se debe dar tratamiento contra la depresión

Si no se proporciona tratamiento, un episodio depresive mayor puede durar entre 6 a 12 meses. Durante el período entre los episodios depresives, la persona por lo general se siente completamente bien (sin síntomas).

A pesar que algunas personas pueden tolerar un episodio depresive sin tratamiento, la mayoría siente que es mucho más sencillo enfrentar este problema con la ayuda de un tratamiento para aliviar el sufrimiento y dolor emocional. Las razones por las que es importante recibir tratamiento contra la depresión son las siguientes:

- El tratamiento temprano puede evitar que la depresión se llegue hacer severa o crónica.
- Los pensamientos del suicidio son comunes durante la depresión, y el riesgo de cometer suicido aumenta en los pacientes que no reciben tratamiento y tienen una recurrencia de la depresión. cuando se da tratamiento eficaz contra la depresión, los pensamientos de suicidio desaparecen.
- Entre los períodos depresives, una de cada cuatro personas aún tendrá algunos de los síntomas y éstos le causarán problemas en realizar las actividades de la vida diaria. Si estas personas no reciben tratamiento, tienen más probabilidad de sufrir otro episodio de depresión.
- El tratamiento (especialmente con medicamentos) puede prevenir las recurrencias. Mientras más episodios de depresión ha tenido una persona, mayor la probabilidad de que padezca otros. Aproximadamente la mitad de las personas que han tenido un episodio depresive, tendrán un segundo episodio. Si no se da tratamiento después de dos episodios, la probabilidad de padecer un tercero (depresión recurrente) es aún mayor. Después de haber tenido tres episodios, la probabilidad de tener un cuarto, es de 90 por ciento.

#### Si tiene dudas sobre su tratamiento

Si en cualquier momento tiene dudas en cuanto a su tratamiento o cree que las cosas no están yendo bien, hable con alguien sobre estas preocupaciones.

Puede:

- Hablar con su médico.
- Pedir una segunda opinión.
- Hablar con alguien en quien confíe.

Los médicos están interesados en su bienestar y le ayudarán. Puede ser necesario que pida una segunda opinión, o que busque un nuevo médico.

### Medicamentos antidepresives

Existen muchos tipos de medicamentos antidepresives que se pueden usar en el tratamiento. Cada uno de estos medicamentos funciona de una manera diferente. Su historial médico, los síntomas, y el historial médico de su familia frecuentemente dan la información en cuanto al tipo de medicamento más indicado en su caso. Aún así, probablemente llevará algún tiempo para encontrar el medicamento más eficaz y que tenga menos efectos secundarios. Usted y su médico encontrarán el mejor medicamento y dosis.

Los medicamentos contra la depresión no crean una adicción. Sirven en el tratamiento contra la depresión severa y a veces son útiles en el tratamiento de la depresión moderada o leve.

Muchas personas empiezan a notar los efectos de los medicamentos incluso en las primeras semanas después de iniciar el tratamiento. Después de 6 semanas, más de la mitad de las personas que toman antidepresives empezarán a sentirse mejor.

Al iniciar su tratamiento, el médico probablemente lo va a querer ver con mayor frecuencia (probablemente cada semana). El propósito de estas visitas es revisar la dosis (cuánto y con qué frecuencia debe tomar el medicamento), para ver si presenta efectos secundarios (otros problemas que le puede causar el medicamento), y para ver el efecto del medicamento contra su depresión.

Una vez que se empiece a sentir mejor, probablemente visitará al médico menos frecuentemente. durante el tratamiento de continuación, probablemente verá al médico una vez cada mes o cada dos meses. durante el tratamiento de mantenimiento, las visitas serán una cada 2 o 3 meses.

Obtendrá mayores beneficios del tratamiento si hace las siguientes cinco cosas:

1. Vaya a todas sus visitas con el médico.
2. Dígale al médico todas sus preguntas.
3. Tome los medicamentos siguiendo las instrucciones de su médico.
4. Dígale al médico de inmediato sobre cualquier efecto secundario causado por el medicamento.
5. Dígale al médico cómo está funcionando el medicamento en su caso.

Vaya a sus visitas médicas aunque se sienta mejor o peor. Si está tomando medicamentos antidepresivos, debe mantener sus visitas médicas para revisar la dosis y los posibles efectos secundarios. Es probable que le sea útil escribir los datos de su medicamento y dosis diaria en la tabla que se le proporciona al final de la publicación. Por ejemplo, puede hacer copias de esta tabla y pegarla en la puerta del refrigerador para que no olvide escribir sus notas.

Dígale al médico todas sus preguntas. Hable con su médico si tiene dudas en cuanto a su medicamento. Las respuestas a algunas de estas preguntas pueden ser importantes para que el médico encuentre el mejor tratamiento en su caso. Recuerde, no hay preguntas "tontas" cuando se trata de su salud.

### Mis preguntas sobre los medicamentos

A continuación se presetan una serie de preguntas que los pacientes hacen frecuentemente cuando están tomando medicamentos. Se proporciona espacio para que pueda escribir las respuestas que le dé el médico. También hay espacio para que pueda escribir sus propias preguntas.

Nombre del medicamento ________________________________________

Dosis/Instrucciones de uso ______________________________

Preguntas que puede hacer cuando está tomando un medicamento

¿Cuándo y con qué frecuencia debo tomar el medicamento?

¿Cuáles son los efectos secundarios de este medicamento?

¿Estaré casado, hambriento, con sueño?

¿Cuáles alimentos no debo comer mientras que esté tomando este medicamento?

¿Puedo tomar cerveza, vino, u otras bebidas alcohólicas?

¿Puedo tomar el medicamento en combinación con las otras medicinas que estoy tomando ahora?

¿Qué debo hacer si se me olvida tomar el medicamento? Otras preguntas¿Por cuánto tiempo tendré que tomar este medicamento?

¿Cuáles son las probabilidades de mejorarse si uno toma este medicamento?

¿Cómo voy a saber si el medicamento está dando resultados o si no está funcionando?

¿Cuánto cuesta el medicamento?

A continuación, escriba sus propias preguntas:

______________________________________________________________

______________________________________________________________

______________________________________________________________

Tome el medicamento siguiendo las instrucciones de su médico, incluso si se empieza a sentir mejor. Es importante que continúe tomando el medicamento para que se siga sintiendo mejor. Probablemente deseará escribir el nombre del medicamento y usar la tabla al final de la publicación para escribir cuándo y cómo lo tomó.

Dígale al médico de inmediato sobre cualquier efecto secundario causado por el medicamento. A pesar que todos los medicamentos tienen algún tipo de efecto secundario, no todos los pacientes los padecen. Algunos pacientes presetan diferentes efectos secundarios que otros. durante las primeras 4 a 6 semanas, los medicamentos antidepresivos causan efectos secundarios en aproximadamente el 50 por ciento de los pacientes que los toman. Normalmente, los efectos secundarios dejan de ser un problema después de este período de tiempo. En muy pocos pacientes los efectos secundarios son tan severos, que es necesario suspender el medicamento.

Los efectos secundarios que presenta cada persona pueden depender de muchas cosas. Estas son:

- El tipo y dosis de medicamento.
- El balance químico del cuerpo.
- La edad.
- Otros medicamentos que esté tomando.
- Otros problemas médicos.

Si los efectos secundarios son un problema para usted, hay varias cosas que el médico puede hacer. El puede:

- Cambiar la dosis del medicamento que está tomando. Algunas veces los efectos secundarios pueden disminuir al reducir la dosis del medicamento que toma el paciente.
- Cambiar el tipo de medicamento que está tomando. El médico puede cambiar a otro medicamento para ver si hay menos, o menos molestos, efectos secundarios.
- Cambiar la hora del día a la que toma el medicamento. A veces los efectos secundarios disminuyen si toma el medicamento en la noche en vez de la mañana.
- Cambiar la forma en que toma el medicamento. Su médico puede recomendarle que tome la dosis en pequeñas cantidades varias veces durante día.

Cambiar medicamentos es una decisión médica compleja. Es peligroso que el paciente trate de hacer estos cambios sin consultar con el médico.

Estos son algunos de los efectos secundarios de los medicamentos antidepresivos:

- Sequedad en la boca.
- Mareo.
- Estreñimiento.
- Urticaria (irritación de la piel).
- Sentir sueño.
- Dificultad para dormir.
- Subir o bajar de peso.
- Sentir inquietud.

Los efectos secundarios más severos son raros. Al igual que los otros efectos secundarios menores, éstos desaparecen después de unas cuantas semanas de tratamiento. Los efectos severos incluyen dificultad para orinar, problemas del corazón, problemas sexuales, convulsiones, desmayos y otros. Tanto los efectos secundarios severos como los leves casi siempre se pueden tratar.

Si usted presenta efectos secundarios, llame a su médico. No espere hasta que le toque su siguiente cita.

Una de cada diez personas que tiene un pariente cercano que ha padecido del trastorno bipolar puede presentar síntomas maníacos durante las primeras semanas de tomar el medicamento. Sólo 1 ó 2 personas de cada 100 que toman antidepresivos presetan este tipo de síntomas si no tienen un pariente que ha padecido de trastorno bipolar. Un sintoma de la mañia es que el paciente se sienta con mucha energía y muy "alegre" o eufórico. Dígale a su médico sobre estos cambios de inmediato.

Dígale a su médico cómo está funcionando el medicamento. Una de las maneras de saber cómo está funcionando el medicamento es el mantener una lista escrita de sus síntomas. Puede hacer esto con la tabla que encontrará en las páginas 32 y 33 de esta publicación. Si el medicamento no está funcionando, es decir que sus síntomas empeoran o no mejoran, su médico probablemente recomendará un examen de sangre para determinar si su cuerpo está recibiendo la cantidad correcta.

Si el medicamento no está surtiendo efecto, hay muchas cosas que se pueden hacer. Entre ellas:

- Ajustar la dosis.
- Cambiar de medicamento.
- Agregar tratamiento de psicoterapia.
- Agregar otro medicamento.

#### cuando el paciente se siente mejor

Tratamiento de continuación. Una vez que el paciente se empieza a sentir mejor, decidirá con su médico si el episodio depresive ha pasado. En la mayoría de los casos, el paciente debe continuar tomando el medicamento antidepresive por varios meses más. La investigación indica claramente que el tratamiento de continuación con medicamento ayuda a prevenir una recaída (o recurrencia) del episodio depresive.

Si el paciente se sigue sintiendo bien después de tener el tratamiento de continuación por 4 a 9 meses, quiere decir que se ha recuperado de la depresión. Si sólo ha tenido un episodio depresive, el tratamiento de continuación se puede suspender con una buena probabilidad de que el paciente seguirá bien. Casi todos los pacientes en tratamiento de continuación se sienten bien durante este período.

Tratamiento de mantenimiento. Algunos pacientes que padecen de depresión tienen que recibir tratamiento de mantenimiento (a largo plazo). Si el paciente ha padecido por lo menos de tres episodios depresives o si padece de trastorno bipolar, necesitará tratamiento de mantenimiento para seguir sano. La investigación indica claramente que el tratamiento de mantenimiento previene un nuevo episodio depresive. Algunos pacientes han tomado medicamentos antidepresivos por 30 años o más sin presentar efecto secundario alguno.

Antes de iniciar un tratamiento de mantenimiento, el paciente y el médico tienen que hablar sobre los costos y los beneficios.

### Psicoterapia

El propósito del tratamiento intensivo con psicoterapia es quitar los síntomas de la depresión y ayudar al paciente a volver a su vida normal. durante la psicoterapia, el paciente trabaja con un profesional de salud calificado (un terapeuta), quien se especializa en enfermedades mentales y quien escucha, habla, y ayuda al paciente a resolver sus problemas. La psicoterapia se proporciona por un período corto y limitado (por ejemplo, de 8 a 20 visitas).

#### Tipos de psicoterapia

La psicoterapia puede ser individual (sólo el paciente y el terapeuta); terapia de grupo (un terapeuta y un grupo de personas con problemas similares); terapia de familia o marital (el terapeuta, los miembros de la familia, los seres queridos, o el conyugue).

El terapeuta da las recomendaciones en cuanto al tipo de psicoterapia más adecuado en cada caso.

Los tres tipos de psicoterapia que se han estudiado más detalladamente en cuanto a su eficacia en el tratamiento de los trastornos depresives son los siguientes:

- Terapia de comportamiento -- Se concentra en los comportamientos del paciente en el momento de la terapia.
- Terapia cognocitiva -- Se concentra en los pensamientos y las creencias del paciente.
- Terapia interpersonal -- Se concentra en las relaciones personales del paciente.

El uso de la psicoterapia como tratamiento único no es recomendable cuando se trata de depresión severa o trastorno bipolar (maniaco depresive). En estos casos es necesario utilizar medicamentos.

#### Para seleccionar un tipo de psicoterapia

Si elige la psicoterapia como tratamiento, tiene que:

- Acudir a sus citas.
- Ser honesto y abierto en sus conversaciones con el terapeuta.
- Tratar de hacer las tareas que se le den como parte de su psicoterapia.
- Decirle al terapeuta la manera en la que está funcionando el tratamiento.

Puede usar la tabla al final de la publicación para mantener una lista de sus citas, actividades y síntomas.

Las terapias de comportamiento, cognositiva e interpersonal normalmente llevan tiempo antes de dar resultados. Aunque la psicoterapia puede empezar a dar resultados de inmediato, algunos pacientes no sienten su efecto total hasta que han pasado entre 8 a 10 semanas. Más de la mitad de los pacientes con depresión leve o moderada responden positivamente al tratamiento con psicoterapia.

De la misma manera que con el tratamiento con medicamentos, es importante recordar que diferentes personas tienen diferentes reacciones a tratamientos similares. Mientras que muchas personas encuentran que la psicoterapia les es benéfica, otras piensan que no lo es. Esto normalmente quiere decir que estas personas necesitan otro tipo de tratamiento.

Si no siente ninguna mejoría después de 6 semanas, o si no se siente totalmente mejor después de 12 semanas, hable con el terapeuta sobre el uso de otros tratamientos.

Psicoterapia de continuación. Si la depresión mejora con el uso de la psicoterapia, el paciente y el terapeuta decidirán si la terapia debe continuar y por cuánto tiempo.

Psicoterapia de mantenimiento. Por lo general, la psicoterapia de mantenimiento (a largo plazo) no se recomienda por sí misma a menos que existan razones por las cuales el paciente no puede tomar medicamentos; tales como el embarazo o el tener efectos secundarios severos.

### Combinación del tratamiento de psicoterapia y medicamentos

En el tratamiento de combinación, los medicamentos se usan para tratar los síntomas de la depresión, y la psicoterapia se usa para ayudar al paciente a encontrar maneras de resolver los problemas que le causa la depresión en su vida personal. Para algunas personas la combinación de tratamientos es muy útil. Más de la mitad de los pacientes bajo terapia de combinación empiezan a sentirse mejor después de 6 a 8 semanas. La terapia de combinación probablemente es más útil: En el tratamiento de depresiones largas; para los síntomas que se presetan entre los episodios depresives; o para los pacientes que no responden bien al tratamiento que usa sólo medicamentos o sólo psicoterapia.

### Otros tratamientos

#### Terapia electroconvulsiva

La mayoría de las depresiones, incluso las severas, se pueden tratar con el uso de medicamentos, psicoterapia o una combinación de ambos. La terapia electroconvulsiva (en inglés "ECT") se usa para deshacerse de los síntomas de la depresión. Se usa principalmente en pacientes que no han respondido al tratamiento con medicamentos antidepresivos. También se puede usar en pacientes que tienen depresión severa y que a la vez tienen otras enfermedades graves. Este tratamiento es mucho menos peligroso que en años pasados. durante el tratamiento electroconvulsivo, se usa anestesia general y medicamentos para relajar los músculos y evitar causar daño. El uso de este tratamiento y los posibles efectos secundarios se deben discutir con un psiquiatra. Al igual que con cualquier otro tratamiento, el psiquiatra se encarga de vigilar el procedimiento y los posibles efectos secundarios.

#### Terapia de luz

En la terapia de luz se usa una luz especial conocida como luz de espectro amplio para darle la impresión al paciente de que tiene varias horas más de luz del sol al día. Para crear esta luz se usan unas cajas o pantallas especiales. Esta terapia puede ser util para las personas que padecen de depresión moderada o leve como resultado del invierno. Hasta que se haya estudiado su efecto más cuidadosamente, el tratamiento debe usarse bajo la recomendación de un especialista .

#### Cómo puede cuidarse a sí mismo el paciente de depresión

cuando está deprimido, es importante que:

- No esté de prisa. No debe forzarse a realizar todas las actividades que hacía antes de deprimirse. Haga un itinerario con metas que pueda lograr ahora.
- Recuerde que tener pensamientos negativos es parte de la depresión (por ejemplo, culparse a si mismo por algo, sentir desesperanza, creer que va a fracasar, etc.). Conforme se cure de la depresión, este tipo de pensamientos desaparecerá.
- Evite tomar decisiones importantes para su futuro cuando esté deprimido. Si debe tomar una decisión importante, pida la ayuda de alguien en quien confíe o de su médico.
- Evite usar drogas o alcohol. La investigación ha demostrado que el uso excesivo del alcohol o las drogas puede causar o empeorar una depresión. También puede disminuir el efecto de los medicamentos antidepresivos, o causar efectos secundarios peligrosos.
- Debe comprender que se llevó tiempo en que le diera la depresión, y que se llevará tiempo en sentirse mejor.

Existe cierta evidencia que el ejercicio, en combinación con el tratamiento, puede ayudar en los casos de depresión leve. Puede solicitar más información sobre cómo puede cuidarse a sí mismo durante la depresión de las organizaciones que se presetan en la contraportada de esta publicación o en libros sobre la depresión que puede encontrar en su biblioteca pública.

### Los beneficios y desventajas del tratamiento

Los tres tipos de tratamiento contra el trastorno depresive mayor que se tratan en esta publicación son:

- Medicamentos antidepresivos.
- Psicoterapia.
- Combinación de medicamentos antidepresivos y psicoterapia.

El resultado de estos tratamientos depende del tipo de depresión, la severidad de la enfermedad, el tiempo que el paciente ha estado deprimido, la reacción de cada individuo al tratamiento, y otros factores.

Los riesgos y beneficios que se describen a continuación son el resultado del conocimiento médico actualizado, usando resultados de estudios de un gran número de pacientes y la opinión de expertos.

Tratamiento | Medicamento añtidepresive* | Psicoterapia | Combinación de medicamentos antidepresivos y psicoterapia
Probabilidades que el tratamiento va a funcionar (ser benéfico) | 50 a 65 por ciento | 45 a 60 por ciento | 50 a 65 por ciento
Probabilidad de efectos secundarios inmediatos o complicaciones (riesgos) | Efectos secundarios leves: 50 por ciento: Efectos secundarios lo suficientemente severos para suspender el tratamiento: 3 a 10 por ciento. | Ninguna | Efectos secundarios leves: 50 por ciento. Efectos secundarios lo suficientemente severos para suspender el tratamiento: 3 a 10 por ciento.
Probabilidades de daños peligrosos a la salud (riesgos) | Menos de 1 por ciento (menos de 1 en cada 100) | Ninguna | Menos de 1 por ciento (menos de 1 en cada 100)

* Las probabilidades que se proporcionan son para el primer medicamento que se ha utilizado. Las probabilidades de que un segundo medicamento sea eficaz también son muy buenas.

### Hablar sobre su tratamiento

Cuando las personas sufren de trastorno depresive mayor, frecuentemente tienen dificultades en el trabajo, la escuela, o con miembros de su familia. Con el tratamiento, sin embargo, eventualmente vuelven a su vida normal.

En algunos trabajos (donde la seguridad de otras personas depende de usted) es importante que les comunique sobre su enfermedad. Usted y su médico pueden hablar sobre lo que les debe decir a su supervisor, maestro o amigos.

#### Su familia y sus amigos

Pídale a sus amigos que le den apoyo, comprensión y paciencia durante su enfermedad. Podría ayudarle el hablar con sus amigos sobre sus sentimientos y el tratamiento, y el pasar tiempo con ellos en actividades sociales. Tenga a la mano el teléfono de personas con quienes tenga confianza de hablar y que le puedan ayudar. Para algunas personas deprimidas, es difícil estar con gente, si usted se siente así, haga cualquier actividad que le ayude a sentirse más animado. Si usted está solo y no puede estar con otra gente, hable con su médico. Para muchos pacientes, la familia es un gran apoyo, especialmente cuando los parientes han aprendido sobre la depresión.

#### Pasar la depresión a los hijos

Los padres se preocupan sobre la probabilidad de que sus hijos van a heredar la depresión. La mayoría de los hijos de personas que padecen de depresión, no padecen de esta enfermedad. La investigación muestra que 1 de cada 7 niños que tienen un padre que ha padecido de varios episodios de trastorno depresive mayor, lo padecerá. Por otra parte, 1 de cada 7 niños con un padre que padece de trastorno bipolar, lo padecerá. Si usted tiene cualquier pregunta en cuanto a la salud mental de sus hijos, hable con su médico.

### Más recursos

Además de las organizaciones que se presetan en la contraportada, el Instituto Nacional de Salud Mental (National Institute of Mental Health), tiene publicaciones gratuitas en inglés y español sobre la depresión. Estas publicaciones son para personas de todas edades, incluyendo a los adolescentes y los ancianos. Escriba a:

- DEPRESSION Awareness, Recognition, and Treatment (D/ART) Program
- Department GL, Room 10-85
- 5600 Fishers Lane
- Rockville, MD 20857
- Llame gratis al: 1-800-421-4211

La Administración Federal de Abuso de Sustancias y Servicios Mentales puede informarle dónde conseguir ayuda en su comunidad: Escriba a:

- SAMHSA Center for Mental Health Services
- Office of Consumer, Family, and Public Information
- Room 15-81
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 443-2792

### Lista semanal de actividades

Puede usar una tabla como esta para escribir los medicamentos, los efectos secundarios, y sus actividades durante la semana. Escribir la información en esta tabla, y compartirla con su médico, ayudará a hacer más eficaz su tratamiento.

Día de la semana | Medicamento que tomé | Efectos secundarios | Síntomas | Actividades | Citas médicas
| Nombre del medicamento: | Cómo me hizo sentir el medicamento | Del 0 (sentirse mal) al 5 (sentirse bien)yo me siento: Mal Bien 0------5 | Actividades del día, incluya los planes y las tareas que le dieron en psicoterapia.
Ejemplo: Lunes 5 de mayo | Una píldora a las 8 de la mañana y otra a las 8 de la noche | Sequedad en la boca | 2 -- Me siento un poco mejor el día de hoy que ayer. | Fui al mercado. Hice una lista de las cosas buenas en mi vida. | Cita con el doctor González a las 3 de a tarde.
Domingo
Lunes
Martes
Miércoles
Jueves
Viernes
Sábado

### Para obtener más información

La información en esta publicación se tomó de Clinical Practice Guideline on Depression in Primary Care, Volumes 1 and 2 (Guía de práctica clínica sobre la depresión en el cuidado primario, Volúmenes 1 y 2). La guía fue desarrollada por un panel privado y de expertos que no trabajan con el gobierno federal, incluyendo a médicos, psicólogos, psiquiatras, trabajadores sociales, enfermeras, consejeros, y personas que padecen depresión. La Guía se desarrolló con el patrocinio de la Agency for Health Care Policy and Research (AHCPR), que es una agencia del Departamento de Salud Publica de los Estados Unidos (U.S. Public Health Service). Se están desarrollando otras Guías en inglés y españ ol sobre problemas comunes de la salud.

Para recibir más copias de esta publicación, o las Guías sobre la depresión, llame gratis al: 1-800-358-9295, o escriba a:

- AHCPR Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, MD 20907