# Las cataratas en los adultos

## ¿Qué son las cataratas?

La catarata es una nebulosidad en el área del lente del ojo. Normalmente el lente del ojo es transparente. El lente deja pasar la luz a la parte de atrás del ojo. Cuando hay una catarata, está no permite que pase la luz y, conforme crece, se le hace cada vez más difícil ver a la persona. Las cataratas son una parte normal del envejecimiento. Aproximadamente la mitad de los americanos de entre 65 a 74 años de edad tienen cataratas. Casí tres de cada cuatro personas mayores de 75 años padecen de esta condición. La mayoría de las personas que tienen cataratas, las tienen en los dos ojos. Sin embargo, uno de los ojos puede estar peor que el otro; porque cada una de las cataratas se desarrolla con diferente rapidez. Algunas personas que tienen cataratas ni siquiera lo saben, porque la catarata puede ser pequeña o probablemente los cambios en su vista no son muy molestos. En cambio, otras personas que tienen cataratas no pueden ver lo suficientemente bien para desempeñar las actividades que necesitan o quieren realizar.

## Guía para el paciente

Esta publicación le puede ayudar a decidir lo que puede hacer si tiene cataratas. Hable con su médico de los ojos para que pueda tomar la mejor decisíon en su caso.

### ¿Cuáles son los síntomas de las cataratas?

Estos son algunos de los síntomas de las cataratas:

- Visíon nublada, desenfocada, o como si viera a través de un velo.
- Cambios en la manera que ve los colores.
- Problemas para manejar un auto de noche, ya que las luces le parecen demasiado brillosas o lo deslumbran.
- Problemas con el brillo de las lámparas o del sol.
- Cambios frecuentes en la graduación de sus anteojos.
- Visíon doble.
- Una mejoría temporal en la vista de las personas que no pueden ver bien de cerca.

Estos síntomas también pueden indicar otros problemas de la vista.

Vea a su médico de los ojos para que le diga lo que padece y los tratamientos disponibles.

### ¿Cómo se diagnostican las cataratas?

Un examen regular de su vista es todo lo que se necesita para encontrar las cataratas. Su médico de los ojos le pediráa que lea un diagrama con letras para determinar qué tan buena es su vista. Probablemente le pondrán gotas en los ojos para agrandar las pupilas (los círculos negros en medio de su ojo). Hacer esto le permite al médico ver dentro de sus ojos. Usando una luz brillante, el médico puede ver si los lentes están transparentes, y puede buscar otros probables problemas en la parte interior de los ojos.

Existen otros exámenes que se pueden realizar ocasionalmente para comprobar cómo la catarata le afecta la vista, o qué tanto mejora su vista después de la operación de catarata:

- Examen de luz brillante.
- Examen de percepción de contrastes.
- Examen de visíon potencial.
- Examen microscópico de fotografía especular.

Sólo algunas personas necesitan estos cuatro exámenes.

### ¿Cuál es el tratamiento contra las cataratas?

A veces el único tratamiento necesario para mejorar su vista es cambiar la graduación de sus anteojos, anteojos bifocales con mayores aumentos, o el uso de lupas (lentes de aumento). Cuando se realiza una operación para el tratamiento de cataratas se quita parte, o la totalidad, del lente del ojo y se reemplaza con un lente artificial.

El hecho que tiene una catarata no necesariamente quiere decir que se le tiene que operar de inmediato. La operación para quitar las cataratas casi siempre se puede posponer hasta que sienta molestias por sus problemas de la vista.

El médico de los ojos le dirá si usted es una de las pocas personas que deben operarse para quitar las cataratas. Por ejemplo, es necesario operar cuando el médico tiene que poder ver, o dar tratamiento, a un problema del ojo que se encuentra escondido detrás de una catarata. También es posible que sea necesario hacer una operación cuando la catarata es tan grande que podría causar ceguera.

### ¿Cómo puedo decidir si quiero que me hagan una operación?

La mayoría de las personas tienen mucho tiempo para pensar sobre la operación de catarata. El médico no puede tomar la decisíon por usted, pero hablar con el le puede ayudar a tomar su propia decisíon.

Dígale a su médico la manera en la que le afectan las cataratas en su vista y en las actividades de su vida diaria. Marque (X) las frases que sean correctas en su caso y enséñele esta lista a su médico:

- Necesito manejar un auto, pero el brillo del sol o las luces me deslumbran demasiado.
- No puedo ver bien y por lo tanto no puedo realizar bien mi trabajo.
- No puedo ver lo suficientemente bien para desempeñar las tareas que tengo que realizar en casa.
- No puedo ver lo suficientemente bien para hacer las cosas que me gusta hacer (por ejemplo, leer, ver la televisíon, coser, ir de paseo, jugar naipes, salir con mis amigos).
- Me da miedo que me voy a golpear con algo y caerme.
- Las cataratas me impiden ser una persona independiente.
- Los anteojos no me ayudan a ver lo suficientemente bien.
- Tengo muchas molestias con mi vista.

Probablemente tenga otros problemas específicos que le gustaría discutir con su médico.

### ¿Qué es lo que debería saber sobre la operación de catarata?

Antes de tomar una decisíon, su médico le hablará sobre las opciones que; tiene en cuanto al tipo de operación más indicada en su caso. También le explicará cómo prepararsé antes de la operación y cómo cuidarse después de está.

La mayoría de los pacientes no se tienen que quedar a dormir en el hospital después de la operación. Probablemente irá a un hospital o centro de consulta externa en donde le harán la operación de catarata y después se puede ir a casa cuando el médico decida que lo puede hacer. Sin embargo, si necesitará que un amigo o un familiar lo lleve a casa; y a alguien que se quede con usted por lo menos un día entero, para ayudarle a seguir las instrucciones de su médico.

La recuperación después de una operación de catarata sé lleva varios meses. Su médico de los ojos lo debe revisar para ver su progreso y asegurarse que tiene los cuidados necesarios hasta que su ojo se haya recuperado completamente.

#### Quitar el lente del ojo

Existen tres tipos de operaciones para quitar el lente del ojo que tiene una catarata:

- Cirugía extracapsular. El cirujano saca el lente del ojo, pero deja en su lugar la parte de atrás de la cápsula (que es la parte exterior del lente).
- Farmacoemulsificación. En este tipo de cirugía extracapsular, el cirujano usa ondas de sonido para suavizar el lente del ojo y así poderlo sacar usando una aguja. La parte posterior de la cápsula del lente se queda adentro.
- Cirugía intracapsular. El cirujano saca el lente del ojo completamente, incluyendo la cápsula. Raramente se usa esta operación.

#### Reemplazar el lente

Generalmente, al mismo tiempo que se hace la operación de catarata, se le coloca al paciente un lente artificial en el ojo. Este es llamado lente intraocular y es un disco de plástico que se coloca en la cápsula del lente dentro del ojo. Otras alternativas incluyen los lentes de contacto y los lentes para cataratas. El médico le ayudará a seleccionar la mejor opción en su caso.

### ¿Se puede volver a formar una catarata?

La catarata no puede volverse a formar porque se ha sacado una parte o todo el lente del ojo. Sin embargo, en la mitad de las personas quienes han recibido la cirugía extracapsular o la farmacoemulcificación, la cápsula del lente se puede nublar. Cuando ocurre este problema en la cápsula del lente, por lo general sucede un año o más después de la operación. La cápsula nublada causa los mismos problemas de la vista que la catarata.

El tratamiento para esta condición se conoce como capsulotomía. Usando un rayo lasér (una luz especial conocida en inglés con las letras "YAG"), el médico hace un hoyo en la cápsula para permitir que pase la luz al interior del ojo. Esta operación no duele y no requiere una estadía en el hospital. La mayoría de las personas pueden ver mejor después de la capsulotomía pero, al igual que con la operación de catarata, pueden haber complicaciones. Su médico le hablará sobre estos riesgos. La capsulotomía no se debe hacer como una medida de prevención.

### ¿Cómo sé si la operación de catarata es apropiada en mi caso?

La mayoría de los pacientes se recuperan de la operación de catarata sin ningún problema y con una mejoría en su vista. De hecho, en la actualidad las complicaciones serias son poco comunes. La operación tiene un índice de éxito de 95 por ciento entre los pacientes que no tienen otros problemas del ojo. Sin embargo, no existen cirugías sin riesgo alguno. A pesar que las complicaciones serias son poco comunes, cuando estas ocurren pueden resultar en pérdida de la vista.

Si usted tiene cataratas en los dos ojos, los expertos piensan que es mejor que espere a que un ojo sane completamente después de la operación antes de que le hagan la operación en el otro ojo. Si el ojo en el que tiene la catarata es el único ojo con que puede ver, usted y su médico deben evaluar cuidadosamente los beneficios y riesgos de la operación de catarata.

Si conoce toda la información, usted mismo puede tomar la decisíon. Pídale a su médico que le explique cualquier cosa que no entienda. No existen preguntas "tontas" en lo que tiene que ver con su salud.

Aquí hay algunas preguntas que pudiera tener:

- ¿Necesito la operación inmediatamente?
- Si no es así, ¿cuánto tiempo puedo esperar?
- ¿Cuáles son los riesgos para mí?
- ¿Qué beneficios puedo esperar?
- Si decido hacerme la operación, ¿qué tipo de operación es la más adecuada en mi caso?
- ¿Qué tipo de reemplazo del lente es el mejor para mí?
- ¿Cuán probable es que se me nuble la cápsula del lente después de la operación de catarata?
- ¿Cuáles son los beneficios y los riesgos de la capsulotomía?

Probablemente quiera escribir algunas otras preguntas para su médico, para que así usted pueda tomar una buena decisíon en cuanto a su tratamiento.

### Beneficios y riesgos de la operación de catarata

#### Actividades que podrá realizar mejor

- Las actividades diarias
- Manejar un auto
- Leer
- Trabajar
- Caminar
- Actividades sociales
- Pasatiempos
- Menos accidentes
- Estar más seguro de sí mismo
- Ser más independiente

#### Posibles complicaciones

- Alta presíon en el ojo
- Acumulación de sangre en el interior del ojo
- Infección adentro del ojo
- Que se dañe o se desplace el lente artificial
- Párpado caído
- Desprendimiento de la retina
- Hemorragia severa en el interior del ojo
- Inflamación, o que se nuble la córnea
- Ceguera
- Perder el ojo

### ¿Cómo puedo informarme más sobre las cataratas?

Fuentes de información:

- American Academy of Ophthalmology
- P.O. Box 7424
- San Francisco, CA 94120-7424
- Teléfono: (415) 561-8500
- Publicación disponible: Catarata: Opacidad de la lente ocular

- American Optometric Association
- Communications Center
- 243 North Lindbergh Boulevard
- St. Louis, MO 63141-7881
- Teléfono: (314) 991-4100
- Publicación disponible: Guía familiar para el cuidado de la vista

- National Eye Institute
- National Institutes of Health
- Bethesda, MD 20892
- Teléfono: (301) 496-5248
- Proporciona información sólo en inglés

- National Society to Prevent Blindness
- 500 East Remington Road
- Schaumburg, IL 60173
- Teléfono: 800-331-2020
- Proporciona información en español

### Para obtener más información

La información en esta publicación está basada en la Clinical Practice Guideline on Cataract in Adults: Management of Functional Impairment (Guía de práctica clínica sobre las cataratas en los adultos: el manejo de la incapacidad funcional). La guía fue desarrollada por un panel de expertos patrocinados por la Agency for Health Care Policy and Research. Existen otras guías para pacientes en inglés y en español sobre problemas comunes de la salud.

Para mayor información sobre las guías, o para recibir más copias de esta publicación, llame al 800-358-9295. Mande una tarjeta postal o carta a:

- Agency for Health Care Policy and Research
- Publications Clearinghouse (OJO)
- P.O. Box 8547
- Silver Spring, MD 20907