# La incontinencia urinaria en los adultos

## La manera en que su cuerpo produce, guarda y desecha la orina

Cuando come y bebe, su cuerpo absorbe líquidos. Los riñones filtran los desperdicios de estos líquidos y producen la orina.

La orina se transporta a un saco de músculos llamado vejiga a través de unos tubos conocidos como ureters. La orina se acumula en la vejiga.

La orina sale de la vejiga a través de un tubo llamado uretra. Cuando orina, usted relaja el esfínter de la uretra y aprieta los músculos de la vejiga. El esfínter de la uretra es un grupo de músculos que se contraen para guardar la orina, y se relajan para dejarla salir.

[image]

[image]

## El propósito de esta publicación

A muchas personas se les sale la orina cuando no lo quieren. Cuando esto sucede tan frecuentemente que se convierte en un problema, la condición se conoce como incontinencia urinaria.

La incontinencia urinaria es muy común, pero a algunas personas les da vergüenza buscar ayuda. Las buenas nuevas son que millones de mujeres y hombres han recibido tratamiento eficaz y se han curado de esta condición.

La información en esta publicación le será útil, pero es muy importante que le diga a su médico o enfermera sobre este problema. Probablemente llevar esta publicación con usted le ayude a hablar sobre su problema de incontinencia.

## Las causas de la incontinencia urinaria

La incontinencia urinaria no es un aspecto normal de la edad avanzada.

Puede suceder a cualquier edad y puede ser el resultado de muchas condiciones físicas. Muchas causas de la incontinencia son temporales y se pueden controlar con tratamientos sencillos. Algunas de las causas de la incontinencia son:

- Infección de las vías urinarias.
- Irritación o infección vaginal.
- Estreñimiento.
- Efectos secundarios de algún medicamento.

La incontinencia puede ser el resultado de otras condiciones que no son temporales. Otras causas de la incontinencia urinaria son:

- Debilidad de los músculos que sostienen a la vejiga en su lugar.
- Debilidad de la vejiga misma. Debilidad de los músculos del esfínter de la uretra.
- Músculos de la vejiga demasiado activos.
- Un bloqueo de la uretra urinaria (puede resultar de la inflamación de la próstata).
- Problemas hormonales de la mujer.
- Desórdenes neurológicos.
- Inmobilidad (que la persona no se puede mover).

En casi todos los casos se puede dar tratamiento para estas condiciones. Su médico le ayudará a encontrar la causa exacta de su incontinencia.

## Tipos de incontinencia

Existen varios tipos de incontinencia urinaria. Algunas personas padecen de más de uno. Comparar sus síntomas con la lista a continuación le debe ayudar a identificar el tipo de incontinencia que padece.

### Incontinencia de urgencia

A las personas que padecen de incontinencia de urgencia se les sale la orina tan pronto cuando sienten la necesidad de ir al baño. Se les puede salir la orina:

- Cuando no pueden llegar al baño rápidamente.
- Cuando toman aunque sea una pequeña cantidad de líquido; o cuando oyen o tocan agua corriente.

También:

- Cuando van al baño frecuentemente. Por ejemplo, cada dos horas, tanto durante el día como en la noche. Probablemente también mojan la cama.

### Incontinencia de tensión

A las personas que padecen de incontinencia de tensión se les sale la orina cuando hacen ejercicio o cuando se mueven de cierta manera. Se les puede salir la orina:

- Cuando estornudan, tosen o ríen
- Cuando se levantan de una silla o la cama.
- Cuando caminan o hacen ejercicio.

También:

- Van al baño frecuentemente durante el día, para evitar accidentes.

### Incontinencia por sensación de sobrecarga

Las personas que padecen de incontinencia por sensación de sobrecarga pueden sentir que nunca llegan a vaciar sus vejigas cuando van al baño. Los que la padecen pueden:

- Perder pequeñas cantidades de orina durante el día y la noche.
- Levantarse frecuentemente en la noche para ir al baño.
- Sentir que tienen que vaciar su vejiga frecuentemente, pero no pueden.
- Orinar sólo un poco, pero sentir como si la vejiga estuviera aún parcialmente llena.
- Estar en el baño por largo tiempo, pero producir sólo un flujo débil y escaso de orina.

Algunas personas que padecen de esta incontinencia no tienen la sensación de tener la vejiga llena, pero tienen accidentes durante el día y la noche.

## Pasos para determinar la causa de la incontinencia urinaria

Una vez que haya hablado sobre su problema de incontinencia con el médico, el siguiente paso es determinar la causa.

Su médico le hará preguntas sobre su historial médico y sus hábitos de ir al baño. Probablemente le pedirá que tome notas sobre su horario de ir al baño (vea el ejemplo de itinerario al final de la publicación). También es probable que le hagan un examen médico y exámenes de orina y otros exámenes indicados. Estos ayudarán a determinar la causa de su incontinencia urinaria y el mejor tratamiento. La tabla al final del folleto tiene una lista de algunos de los exámenes médicos más comunes.

Ejemplo de las notas sobre los hábitos para ir al baño

Los exámenes médicos más comunes para diagnosticar la incontinencia urinaria

Nombre del examen | Propósito
Examen de la sangre | Analiza el nivel de ciertos químicos en la sangre.
Cistoscopía | Con este examen se buscan anormalidades en la vejiga en la parte baja de las vías urinarias. El médico mira en el interior del sistema urinario usando un tubo que tiene un telescopio (una pequeña cámara) que se introduce en la vejiga[*].
Medida de orina después de orinar | Se mide la cantidad de orina que queda en la vejiga después que la persona orina. Se usa un pequeño y suave tubo que se introduce en la vejiga o el ultrasonido (ondas de sonido).
Prueba de tensión | Se observa la pérdida de orina cuando se pone presión en los músculos de la vejiga, normalmente haciendo qu la persona tosa, levante algo, o haga ejercicio.
Análisis de orina | Se analiza la orina para buscar infecciones, sangre, u otras cosas fuera de lo normal.
Prueba de dinámica vesical | Se examina el funcionamiento de la vejiga y el esfínter de la orina (probablemente se use un tubo que se introduce en la vejiga, o rayos-x).

[*]Como es probable que esta parte del examen le cause molestias, probablemente le darán medicamentos para relajarlo(a).

## Tratamientos para la incontinencia urinaria

Una vez que se ha determinado el tipo y la causa de su incontinencia urinaria, se puede empezar el tratamiento. La incontinencia urinaria se puede tratar de una de tres maneras: Técnicas de control, medicamentos y cirugía.

### Técnicas de control:

Estas técnicas le enseñan formas de controlar su propia vejiga y los músculos del esfínter de la orina (vea la ilustración al principio de la publicación). Estas técnicas son sencillas y eficaces en el tratamiento de ciertos tipos de incontinencia urinaria. Existen dos tipos de técnicas de control que se usan frecuentemente:Entrenamiento de control de la vejiga y ejercicios del músculo pélvico. También es posible que le pidan que cambie la cantidad de líquidos que bebe; ya sea para que beba más, o menos agua, dependiendo de su tipo de problema.

Entrenamiento de control de la vejiga. Se usa para dar tratamiento a la incontinencia de urgencia y también puede usarse en el tratamiento de la incontinencia de tensión. Las personas aprenden diferentes maneras de controlar su urgencia por orinar. Un ejemplo es la distracción (pensar en algo diferente). Otra técnica que también se usa es conocida como horario para vaciar la vejiga; que quiere decir que la persona tiene un horario específico para ir al baño. Esta técnica ha resultado ser muy eficaz para ayudar a los pacientes en asilos de ancianos.

Ejercicios del músculo de la pelvis. También conocidos como ejercicios Kegel, se usan para el tratamiento de la incontinencia de tensión. Estos ejercicios ayudan al paciente a fortalecer los músculos que rodean a la vejiga.

### Medicamentos

Algunas personas necesitan tomar medicamentos para el tratamiento de las condiciones que causan el problema. Los que se usan con mayor frecuencia son para el tratamiento de: Infecciones, para reemplazar hormonas, para evitar que el músculo de la vejiga tenga contracciones anormales, o para fortalecer los músculos del esfínter. Su médico le dirá si necesita usar medicamentos y cómo y cuándo tomarlos.

### Cirugía

La cirugía (una operación) a veces es necesaria para ayudar a dar tratamiento a las causas de la incontinencia. La cirugía puede:

- Volver a colocar el cuello de la vejiga en su lugar adecuado (en las mujeres que padecen de incontinencia de tensión).
- Quitar el tejido que provoca un bloqueo.
- Componer los músculos débiles de la pelvis.
- Agrandar la vejiga para que pueda guardar más orina.

Existen muchos diferentes procedimientos de cirugía que se pueden usar en el tratamiento de la incontinencia urinaria. El tipo de operación que le recomendarán depende del tipo y causa de su incontinencia. Su médico le hablará sobre el procedimiento específico que es necesario para su tratamiento.

Haga todas las preguntas necesarias hasta que entienda claramente el procedimiento de la operación

## Otras medidas y materiales para la condición

Hay otros productos que puede usar para ayudar a controlar la incontinencia, tales como toallas sanitarias y catéters. Los catéters se usan cuando la persona no puede orinar. El catéter es un tubo que se introduce en la vejiga para sacar la orina a una bolsa de plástico fuera del cuerpo. Normalmente el catéter se deja dentro de la vejiga, pero no siempre. Los catéters se introducen o se sacan de la vejiga conforme es necesario vaciarla después de algunas horas. Los catéters de condón (que se usan principalmente en hombres) se prenden a la parte exterior del cuerpo y no se colocan directamente dentro de la vejiga. Existen toallas sanitarias especiales que usan los hombres y las mujeres para la incontinencia urinaria.

Los catéters y las toallas sanitarias no son los únicos tratamientos para la incontinencia. Sólo se deben usar para hacer que otros tratamientos sean más eficaces, o cuando otros tratamientos no han tenido éxito.

## El siguiente paso

Su médico o enfermera le hablará sobre el tipo de incontinencia urinaria que padece y le dará recomendaciones de tratamiento. Mientras que recibe tratamiento, usted tiene que:

- Hacer preguntas.
- Seguir instrucciones.
- Tomar todos los medicamentos que le den.
- Llamar a su médico o enfermera y decirle sobre cualquier efecto secundario (molestia) que le ocasione el medicamento.
- Llame a su médico o enfermera y dígale sobre cualquier cambio, bueno o malo.

...y recuerde, la incontinencia urinaria no es una parte normal de avanzar en edad. En la mayoría de los casos, se puede dar tratamiento.

## Riesgos y beneficios de los tratamientos

Se recomiendan tres tipos de tratamiento para la incontinencia urinaria:

- Técnicas de control
- Medicamentos
- Cirugía

La eficacia de estos tratamientos depende de la causa de la incontinencia y, en algunos casos, el esfuerzo del paciente. Los riesgos que se describen a continuación se basan en el conocimiento médico actual. El éxito del tratamiento también depende de cada individuo. Un tratamiento que ha sido eficaz con un paciente probablemente no lo sea con otro. Es por esto que es importante hablar con su médico sobre las opciones de tratamiento.

Técnicas de control. No existen riesgos para el paciente en este tipo de tratamiento.

Medicamentos. Como es el caso con cualquier medicamento, existe la posibilidad de tener efectos secundarios. Si está tomando medicamentos para otros problemas de salud, la combinación con la medicamentos para la incontinencia puede causar una reacción; por eso es importante que hable con su médico o enfermera sobre todos los medicamentos que toma, y que le diga de inmediato sobre cualquier efecto secundario que presente.

Cirugía. Como es el caso con cualquier cirugía, existe el riesgo de que se presenten complicaciones; por eso es importante que hable sobre estos riesgos con su cirujano.

## Organizaciones de apoyo para personas con incontinencia urinaria

Existen varias organizaciones nacionales que ayudan a las personas que padecen de incontinencia urinaria. Estas organizaciones le pueden poner en contacto con grupos locales que le proporcionarán más información, ideas, y apoyo emocional para tolerar la incontinencia urinaria. Pregunte si cuentan con servicios en español.

- Alliance for Aging Research
- 2021 K Street, N.W.
- Suite 305
- Washington, DC 20006
- (202) 293-2856
- Bladder Health Council
- c/o American Council for Urologic Disease
- 300 West Pratt Street, Suite 401
- Baltimore, MD 21201
- (800) 242-2383
- (410) 727-2908
- Help for Incontinent People
- P.O. Box 544
- Union, SC 29379
- (803) 579-7900
- International Continence Society
- 2 Doughty Street
- London WC1N 2PH
- 44-714046875
- Simon Foundation for Continence
- Box 835
- Wilmette, IL 60091
- (800) 237-4666

## Para más información

La información en este folleto se tomó de la Guía de práctica clínica sobre la incontinencia urinaria en los adultos La Guía fue escrita por un panel de médicos, enfermeras, otros profesionales de la salud y consumidores patrocinados por la Agency for Health Care Policy and Research. En el futuro, la Agencia escribirá y publicará guías sobre otros problemas de salud comunes. Para obtener más información sobre las guías, o para recibir más copias de este folleto, llame o escriba a:

- Agency for Health Care Policy and Research,
- Publications Clearinghouse,
- Post Office Box 8547,
- Silver Spring, MD 20907,
- (800) 358-9295,
- (301) 495-3453.