# Formas de controlar el dolor después de una operación Guía para el paciente

## ¿Qué es el dolor?

El dolor es la forma en la que el cuerpo le manda una señal al cerebro indicando que puede haber un problema. Su columna vertebral (la espina) y los nervios de su cuerpo son los conductos a través de los cuales se transmiten las sensaciones del cuerpo al cerebro y del cerebro al resto del cuerpo.

Las células debajo de la piel y en la piel sienten el calor, el frío, la luz, la forma y textura de las cosas, la presión y el dolor. Todas las personas tienen miles de estas. Cuando hay una herida en el cuerpo -- en este caso una operación (cirugía) -- estas pequénas células mandan mensajes de dolor al cerebro. La medicina contra el dolor bloquea estos mensajes de dolor o reduce su efecto en el cerebro.

Si el dolor no se le quita -- incluso después que le han dado medicina -- puede indicar que existe un problema. Después que le hacen una operación, su médico o enfermera le preguntará si siente dolor. Asegúrese de decirles si siente dolor.

Este documento es de dominio público y se puede reimprimir sin permiso previo. AHCPR agradecerá que se le presente como fuente de citas bibliográficas. A continuación se encuentra el formato de cita sugerido:

- Acute Pain Management Guideline Panel.
- Formas de controlar el dolor después de una operación.
- Guía para el paciente.
- AHCPR Pub. No. 92-0068. Rockville, MD: Agency for Health Care Policy and Research.
- Public Health Service, U.S. Department of Health and Human Services. Sept. 1992.

## Guía para el paciente

### El propósito de este folleto

Este folleto trata sobre las formas de aliviar el dolor después de una operación (cirugía) y los tipos de tratamiento que probablemente recibirá. El folleto también le muestra cómo puede cooperar con sus médicos y enfermeras.

Leer este folleto le debe ayudar a:

- Aprender que controlar el dolor es importante.
- Ser capaz de ayudar a sus médicos y enfermeras a decidir la mejor forma de controlar su dolor.

### Las metas del tratamiento

No tiene porqué sentir dolor severo después de una operación. Coopere con sus médicos y enfermeras antes y después de su operación para prevenir y aliviar el dolor.

#### El control del dolor le puede ayudar a

- Tener menos molestias mientras sana.
- Sanar más rápidamente. Como siente menos dolor, puede empezar a moverse y recuperar su fuerza más rápidamente.
- Mejorar los resultados de su operación. Las personas que sienten menos dolor parecen recuperarse mejor después de una operación.

#### ¿Cuáles son las opciones para controlar el dolor?

Tanto los tratamientos en los que se usan medicinas como en los que no se usan medicinas ayudan a prevenir y controlar el dolor eficazmente. Los métodos más comunes para controlar el dolor se describen a continuación. Usted y sus médicos decidirán cuáles métodos son los mejores en su caso.

No se preocupe sobre la posibilidad de Óvolverse adictos a las medicinas contra el dolor. Los estudios científicos muestran que esto sucede raramente.

### Los métodos de control del dolor que se pueden usar

Los médicos y enfermeras quieren que usted sienta mínima molestia como resultado de su operación, pero usted debe ayudarles. Usted es la única persona que sabe cuánto dolor siente y cómo lo hace sentirse.

#### Antes de la operación

Tratamiento con medicinas: Tomar una medicina contra el dolor.

Tratamiento sin medicinas: Entender el tipo de operación que se va a hacer, porqué se tiene que hacer y cómo se va a hacer. Aprenda a hacer ejercicios especiales que le ayudarán a relajarse.

#### Durante la operación

Tratamiento con medicinas: Recibir anestesia general (lo duermen), anestesia en la columna vertebral (la espina), medicina para bloquear los nervios, o dar una medicina para el dolor a través de un tubo colocado en la columna vertebral (llamada anestesia epidural).

#### Después de la cirugía

Tratamiento con medicinas: Tomar una medicina contra el dolor como una pastilla, una inyección, o a través de un tubo colocado en su vena o en su columna vertebral.

Tratamiento sin medicinas: Usar masaje, compresas calientes o frías, ejercicios de relajamiento, música, y otros métodos que ayuden a distraerle del dolor.

#### ¿Qué puede hacer para ayudar a controlar su dolor?

Los siguientes siete pasos le pueden ayudar. Posiblemente le ayudaría escribir sus preguntas antes de hablar con el médico o enferma.

#### Antes de la operación

1. Pregúntele a su médico o enfermera lo que probablemente va a suceder.

- ¿Sentirá mucho dolor después de la operación?
- ¿En qué parte del cuerpo le dolerá?
- ¿Cuánto tiempo durará el dolor?

2. Hable sobre las opciones para controlar el dolor (en la página 3) con sus médicos y enfermeras.

Asegúrese de:

- Hablar sobre los métodos para controlar el dolor que le han dado en el pasado y cuáles de ellos han servido y cuáles no.
- Hablar sobre cualquier preocupación especial que tenga en cuanto a la medicina contra el dolor que le van a dar.
- Hablar sobre las medicinas que le hacen daño.
- Preguntar sobre los efectos secundarios que puede causar el tratamiento.
- Hablar sobre las medicinas que toma actualmente para sus problemas de salud.

3. Hable sobre el horario en el que se dan medicinas contra el dolor en el hospital.

A algunas personas sólo se les da medicina contra el dolor en el hospital cuando las piden. Probablemente tendrán que esperar a que les den la medicina, y el dolor empeorará mientras esperan.

Hoy en día hay dos horarios para dar medicinas que parecen tener mejores resultados.

- Dar las medicinas o las inyecciones contra el dolor a horas fijas, incluso si no siente dolor.
- Usar el método de "medicina contra el dolor controlada por el paciente" (en inglés conocido como "patient controlled analgesia" -- PCA). Cuando empieza a sentir dolor, usted mismo presiona un botón para obtener medicina en la vena.

En cualquiera de estos casos, sus enfermeras o médicos le preguntarán cómo está funcionando la medicina. Si aún siente dolor, ellos harán los cambios adecuados.

4. Coopere con sus médicos y enfermeras para tener un plan para controlar el dolor.

Ellos necesitan su ayuda para diseñar el mejor plan para usted. Puede usar el modelo en las páginas 8 y 9 de este folleto para escribir lo que sucederá. Guarde este folleto para que le sirva como guía en caso que necesite otra operación en el futuro.

#### Después de la operación

5. Tome (o pida que le den) medicinas contra el dolor cuando empiece a sentir dolor. Esto es un paso importante en el control del dolor.

- Tome, o pida, la medicina tan pronto empiece a sentir dolor.
- Si sabe que el dolor empeorará cuando empiece a moverse, tome la medicina antes de hacerlo.

6. Ayude a los médicos y enfermeras a "medir" su dolor.

- Le pueden pedir que califique su dolor en una escala del 0 al 10 ("0" cuando no le duele y "10" cuando le duele mucho).
- Le pueden pedir que use una escala para medir el dolor: como la que se presenta en la página 7.
- Esto le permitirá saber a los doctores y enfermeras si el tratamiento está funcionando y si es necesario hacer cambios.

7. Dígale al médico o la enfermera si siente cualquier dolor que no desaparece.

- No se preocupe de ser una molestia para los médicos o las enfermeras.
- El dolor puede indicar que existen problemas con su operación.
- Los médicos y las enfermeras quieren y necesitan saber si tiene dolor.

Si su plan de control del dolor le ha ayudado, siga usándolo. Sus médicos pueden cambiar el plan si el dolor no está bajo control. Usted les tiene que decir sobre su dolor y si el plan para controlarlo está funcionando.

### Plan para controlar el dolor

su nombre

Antes de la operación, me van a dar

nombre(s) de la(s) medicina(s)

Instrucciones de uso de la(s) medicina(s):

Después de la operación, voy a tomar, o me van a dar.

nombre(s) de la(s) medicina(s)

en el hospital.

Me darán la(s) medicina(s):

en píldora(s)a través de la vena

en inyección(es)

a través de un tubo en mi columna vertebral (la espina).

Me darán la(s) medicina(s):

con un horario a tiempos fijos cadahoras, durantedías: las 24 horas del día cuando yo llame a la enfermera.

También voy a usar los siguientes métodos de control del dolor sin usar medicinas en el hospital y en mi casa:

En mi casa, voy a tomar

nombre(s) de la(s) medicina(s)

Instrucciones de uso de la(s) medicina(s) en mi casa:

### Para más información

La información en este folleto se tomó de la Guía de práctica clínica sobre el control del dolor intenso: procedimientos quirúrgicos o médicos y trauma. La Guía fue escrita por un panel de médicos, enfermeras, otros profesionales de la salud, un profesional en etica y un representante de consumidores (no empleados por el gobierno federal) patrocinados por la Agency for Health Care Policy and Research (AHCPR), una agencia del Servicio de Salud de los Estados Unidos. En el futuro, la Agencia publicará guías sobre otros problemas comunes de la salud.

Para obtener más información sobre las guías, o para recibir más copias de este folleto, llame al 1-800-358-9295, o escriba a AHCPR Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907.

## Dibujos

### El propósito de este folleto

[image]

### Escala de números para medir la intensidad del dolor

[image]