# La recuperación de los problemas cardíacos a través de la rehabilitación

## Rehabilitación * * Nota para el lector o la lectora: Las recomendaciones en esta publicación son para los hombres y las mujeres.

Figure: "La Recuperación cardíaca a través de la rehabilitación"

- Ejercicio:
- Realizar actividades físicas regularmente que sean adecuadas para sus habilidades, necesidades e intereses.
- Educación:
- Aprender todo lo posible sobre su problema del corazón, sus causas, tratamientos y necesidades de cuidado.
- Consejería:
- Hablar con expertos sobre los cambios que le permitirán reducir el riesgo de sufrir más problemas.
- Cambios en sus hábitos:
- Aprender a cambiar sus malos hábitos, tales como fumar, y elegir mejores hábitos, como adoptar una alimentación que le ayude a mantenerse sano.

## El propósito de esta publicación

Los servicios de rehabilitación para los problemas cardíacos están diseñados para permitir que los pacientes se recuperen más rápido y puedan volver a tener una vida activa y productiva. Estos servicios incluyen ejercicio, educación, consejería, y el aprender formas de vida que le permitan mantenerse saludable. Además de los tratamientos médicos y las cirugías, los servicios de rehabilitación cardíaca le pueden ayudar a sentirse mejor y más saludable.

Usted se puede beneficiar de estos servicios si:

- Padece de una enfermedad como la angina de pecho o insuficiencia cardíaca, o si ha sufrido un ataque al corazón (infarto).
- Le han hecho una cirugía de puente cardíaco ("bypass") o una angioplastia (cateterización de globo).
- Si le han hecho un transplante de corazón.

La rehabilitación cardíaca puede cambiar su vida. Es la manera más eficaz y segura para que le ayuden. Usted:

- Se sentirá mejor más rápido.
- Tendrá más fuerza.
- Tendrá menos tensión emocional.
- Reducirá el riesgo de sufrir otros problemas cardíacos en el futuro.
- Prolongará su vida.

La mayoría de las personas con un problema del corazón se pueden beneficiar con algún tipo de rehabilitación. Nadie es demasiado viejo o demasiado joven; y las mujeres se pueden beneficiar tanto como los hombres.

Esta publicación le puede ayudar a aprender formas de reducir su riesgo de tener problemas cardíacos en el futuro. También le daremos recomendaciones en cuanto a cómo encontrar los mejores servicios de rehabilitación cardíaca para usted.

Lo más importante es que usted mismo aprenderá a cuidarse y a mantenerse más sano.

Cuando padece de un problema del corazón, cambiar sus hábitos de vida y aprender nuevas formas de hacer las cosas le puede causar tensión emocional. La incertidumbre en cuanto a su futuro también le puede causar tensión. Sin embargo, con la ayuda de su familia y amigos; y con la supervisión de sus médicos, enfermeras y otros proveedores de cuidado podrá adaptarse con menos dificultad. Comparta esta publicación con familiares y amigos para que aprendan sobre la rehabilitación cardíaca y cómo le pueden ayudar durante este período.

## Los factores de riesgo de las enfermedades coronarias

A continuación se presentan los factores de riesgo de las enfermedades coronarias. Existen algunos factores de riesgo que no puede cambiar, como el envejecer, o un historial médico de enfermedades cardíacas en su familia. Sin embargo, existen muchos factores que sí puede cambiar. En estos casos, los servicios de rehabilitación cardíaca le pueden ayudar.

Factores de riesgo de las enfermedades coronarias que puede controlar

- Fumar
- Alta presión sanguínea
- Niveles altos de colesterol
- Falta de actividad física
- Ser demasiado pesado
- Diabetes

## El grupo de cuidado médico de rehabilitación

El grupo de rehabilitación cardíaca puede constar de muchos profesionales en el área del cuidado médico. Entre ellos, pueden encontrarse:

- Médicos (el médico de cabecera, el especialista en enfermedades cardíacas, quizás un cirujano).
- Enfermeras.
- Especialistas en ejercicio.
- Especialistas en terapia física y ocupacional.
- Especialistas en dietética (alimentación).
- Psicólogos, u otros especialistas

A veces su médico de cabecera, o una enfermera registrada, trabaja solo, desempeñando varias tareas necesarias para su cuidado médico, o proporcionándole las referencias para consultar a otros especialistas conforme es necesario.

Sin embargo, la persona más importante en este grupo de cuidado médico es usted, el paciente. Nadie le puede forzar a hacer ejercicio, o a dejar de fumar, o a cambiar su alimentación.

Para participar en su grupo de rehabilitación cardíaca, usted tiene que:

- Aprender sobre su problema(s) cardíaco.
- Aprender sobre lo que puede hacer para mejorar su condición.
- Seguir el plan de tratamiento.
- Hacer todas las preguntas que sean necesarias.
- Reportar los problemas y síntomas.

Un grupo de apoyo le puede ayudar. Este puede constar de familiares, amigos, u otras personas que también tienen problemas cardíacos.

Sus amigos y familiares pueden ayudarle mucho. Probablemente ellos desearán aprender más sobre los problemas cardíacos para así proporcionar el apoyo más adecuado. Por ejemplo, sus familiares tendrán que aprender a no preocuparse y dejarle hacer las cosas por usted mismo; o pueden aprender a preparar comidas que sean más saludables para su corazón. Su familia o amigos le pueden dar apoyo moral conforme se adapta a los cambios para mejorar su estilo de vida.

Probablemente también deseará tener el apoyo de otras personas que han tenido problemas cardíacos. Hable con los miembros de su grupo de rehabilitación cardíaca para encontrar un grupo de apoyo en el que pueda participar; o también puede ponerse en contacto con alguna de las organizaciones que se presentan al final de esta publicación.

## ¿Por dónde puedo empezar?

El proceso de rehabilitación cardíaca frecuentemente se inicia en el hospital, inmediatamente después que el paciente ha tenido un ataque cardíaco, una cirugía del corazón, y otros tratamientos para el corazón. La rehabilitación continúa en consulta externa (ambulatoria) después de que el paciente sale del hospital. Una vez que ha aprendido los nuevos hábitos y cambios para mantener su salud cardíaca, los debe seguir por el resto de su vida.

- Servicios para el paciente de consulta externa. Los servicios de consulta externa pueden estar ubicados en un hospital, en un centro médico o de cuidado médico, en una organización de la comunidad como la "YMCA" o en su lugar de trabajo. Usted puede recibir rehabilitación cardíaca incluso en su hogar. Le recomendarán que gradualmente aumente el ejercicio. También recibirá educación e información y le darán apoyo emocional y ánimo. Esto le ayudará a controlar sus factores de riesgo.

- Cambios para toda la vida. Después de haber aprendido los nuevos hábitos y cambios apropiados para su salud, debe seguirlos de por vida.

Usted necesita la autorización de su médico para iniciar servicios de rehabilitación cardíaca. Dígale a su médico o enfermera que está interesado en iniciar servicios de rehabilitación cardíaca y pregúntele cuáles servicios son los mejores en su caso.

## ¿En qué consiste la rehabilitación cardíaca?

La rehabilitación cardíaca consiste de dos partes principales:

1. Entrenamiento de ejercicio físico para ayudarle a aprender a hacer ejercicio de una manera segura y saludable, fortalecer sus músculos, y mejorar su resistencia física. El plan de ejercicio responderá a sus habilidades, necesidades e intereses personales.
2. Educación, consejería, y capacitaciónque le permitirán entender su problema cardíaco y encontrar maneras para reducir el riesgo de tener otros problemas cardíacos en el futuro. El grupo de rehabilitación cardíaca le ayudará a aprender a tolerar la tensión emocional al tratar de adaptarse a su nuevo estilo de vida.

Los servicios de rehabilitación cardíaca generalmente se imparten en grupos, pero en el plan de cada paciente siempre se toman en cuenta sus necesidades individuales y sus factores de riesgo específicos.

La rehabilitación cardíaca le ayuda a identificar los malos hábitos de vida que tiene, y a cambiarlos por hábitos saludables. Sus servicios de rehabilitación pueden durar 6 semanas, 6 meses, o incluso más tiempo. Es importante que continúe con todos los elementos de su rehabilitación cardíaca hasta que hayan terminado.

Aunque parezca que su rehabilitación es difícil, este esfuerzo le brindará beneficios para toda la vida.

## ¿Existe algún peligro?

La rehabilitación cardíaca no es peligrosa. Los estudios indican que los problemas serios de salud que resultan de los ejercicios de rehabilitación son raros. El grupo de rehabilitación cardíaca está capacitado para manejar las emergencias que se puedan presentar. Además, su médico le puede ayudar a elegir los mejores y más seguros servicios en su caso. Una vez que se ha establecido un plan individual, muchos pacientes pueden hacer ejercicio sin correr peligro, y sin necesidad de supervisión.

Evaluar la reacción y adaptación de su corazón al ejercicio es una parte importante de la rehabilitación cardíaca. Para hacer esto, puede ser que le conecten a una máquina de electrocardiograma (muestra en papel los latidos y funcionamiento de su corazón) mientras realiza ejercicio. Si su rehabilitación se lleva a cabo en casa, lo pueden conectar con un monitor especial en el hospital a través de la línea telefónica; o puede ser que usted tenga que llamar por teléfono al grupo de rehabilitación para reportar su condición. En otras circunstancias, usted mismo revisa su pulso o evalúa qué tanto esfuerzo está realizando en el ejercicio.

## ¿Cuáles son los beneficios para mí?

Las metas de cada plan de rehabilitación cardíaca son diferentes para cada paciente. Al establecer sus propias metas, el grupo de rehabilitación toma en cuenta su salud general, su problema cardíaco específico, los factores de riesgo, las recomendaciones de su médico y, por supuesto, sus propias preferencias.

La rehabilitación cardíaca puede reducir sus síntomas y la probabilidad que presente otros problemas cardíacos en el futuro. Tiene muchos otros beneficios.

- El ejercicio mejora sus músculos, le da más energía y le hará sentirse mejor emocionalmente. Ayuda a su corazón y le da más fuerza a su cuerpo. El ejercicio también le permitirá regresar al trabajo y otras actividades más pronto.

- Una alimentación saludable puede reducir el nivel de colesterol en su sangre, controlar el peso, y ayudarle a controlar su presión sanguínea y otros problemas tales como la diabetes. Además, se sentirá mejor y tendrá más energía.

- Los servicios de rehabilitación le pueden ayudar a dejar de fumar. Dejar de fumar reduce el riesgo de padecer de enfermedades tales como el cáncer de pulmón, enfisema, y bronquitis. También reduce la probabilidad de tener ataques cardíacos, ataques cerebrales, y otros problemas cardíacos y de los vasos sanguíneos. Tendrá más energía y salud.

- Puede aprender a manejar mejor las situaciones que le causan tensión emocional y tener mejor control de su vida. Sentirse bien emocionalmente le ayudará a mejorar la condición de su corazón.

El ejercicio aeróbico aumenta el ritmo de su pulso y le hace perspirar (sudar). Mejora la circulación de la sangre rica en oxígeno a todas las partes del cuerpo. El entrenamiento con pesas aumenta la fuerza muscular y su tolerancia.

Ambos tipos de ejercicio, cuando se hacen adecuadamente, son seguros y benéficos para el corazón.

Su vida depende de su capacidad de hacer hábitos cotidianos de todas las recomendaciones de sus servicios de rehabilitación.

## ¿Cómo encontrar los servicios más adecuados?

Su médico o enfermera puede recomendarle un programa en particular o ayudarle a hacer los arreglos para recibir entrenamiento para ejercicios, educación, consejería y otros servicios relacionados. Muchos hospitales y centros de servicios ambulatorios ofrecen rehabilitación cardíaca; y ciertas escuelas locales y centros comunitarios también los ofrecen. Usted mismo puede consultar el directorio de teléfonos (las páginas amarillas) para encontrar servicios.

Cuando elija servicios de rehabilitación, haga las siguientes preguntas:

- La hora en que se imparte. ¿Ofrecen los servicios a una hora que le es conveniente y no le causa más problemas? A veces, los servicios en el lugar de trabajo son una buena opción.
- Lugar. ¿Le es fácil llegar al lugar donde se imparten los servicios? Recuerde que los problemas de tráfico o el uso de transportación pública pueden causarle tensión emocional. ¿Hay dónde estacionarse? ¿La transportación pública es adecuada para llegar ahí?
- Tipo de servicios. ¿Son individuales o se imparten en grupos? ¿Se pueden impartir en el hogar, o es en otra lugar? Piense si usted prefiere participar en un grupo con la supervisión profesional adecuada.
- Contenido de los servicios. ¿Ofrecen una amplia variedad de actividades? Aun más importante, ¿cubre los temas que le son importantes, tales como dejar de fumar?
- Costo. ¿Tiene un precio accesible para sus recursos? ¿Lo cubre la compañía de seguro de salud? Su compañía de seguro de salud probablemente cubrirá parte o todo el costo de algunos servicios, pero no de otros. Averigue cuáles costos serán cubiertos por la aseguradora y por cuánto tiempo. Considere lo que usted pueda pagar, y por cuánto tiempo.

Los beneficios de rehabilitación cardíaca son para toda la vida, así es que es recomendable que elija los mejores servicios en las áreas en donde usted necesita mayor ayuda. Por ejemplo, si usted fuma, busque un programa que le ayude a dejar de hacerlo. Elija servicios que incluyan actividades que usted disfrute, tales como caminatas en un centro comercial o en un parque. Antes de inscribirse, visite el centro de rehabilitación o de servicios y pregunte todo lo que quiera saber.

## ¿Cómo puede obtener los mayores beneficios?

Los estudios demuestran que si el paciente puede controlar los factores de riesgo para los problemas del corazón, puede disfrutar una vida más saludable. Por ello es importante que los servicios de rehabilitación cardíaca que elija le ofrezcan todo lo que necesita. Los siguientes son puntos importantes:

- Plan. Coopere con su grupo de cuidado médico para diseñar o cambiar los servicios de rehabilitación de tal manera que respondan a sus necesidades.
- Comunicación. Haga preguntas. Si no entiende las respuestas, insista hasta que todo le quede claro. Reporte cualquier cambio en su estado físico o emocional.
- Tome cargo de su recuperación. Nadie más lo puede hacer en su lugar. Los cambios en su estilo de vida son benéficos para su corazón, así es que debe mantenerlos para siempre.

Para tener mayor control sobre la dirección de su rehabilitación, recuerde las metas y mantenga la información importante a la mano. Puede ser que le sirva tener un calendario para anotar las actividades de su plan, o tener un cuaderno tal como el que se muestra en las siguientes hojas.

[image]

A veces, las personas que tienen que cambiar sus vidas radicalmente se sienten deprimidas. Algunas personas se sienten deprimidas cuando se les diagnostica, o después de la cirugía. La rehabilitación le puede ayudar a sentirse mejor, pero si se siente muy deprimido, es probable que necesite más ayuda. La depresión hace más difícil que haga las cosas que le pueden ayudar a mejorarse, como acudir a sus servicios de rehabilitación o volver a iniciar sus actividades normales. Si está deprimido, consulte a su médico, ya que existen tratamientos para este problema. Al final de esta publicación le damos información sobre una publicación en español sobre el tema.

## Para obtener más información y apoyo:

Para mayor información sobre las enfermedades cardíacas y maneras en las que puede obtener ayuda a través de los servicios de rehabilitación, consulte a:

- American Association of Cardiovascular and Pulmonary Rehabilitation
- (directorio de programas a nivel nacional, sólo en inglés), 608-831-7561
- American Heart Association
- (Materiales de educación al paciente en español), 800-242-8721
- Mended Hearts, Inc.
- (grupos de apoyo al paciente en español y materiales educativos en español), 214-706-1442
- National Heart, Lung, and Blood Institute
- (Materiales de educación al paciente en español), 301-251-1222

## Para obtener más información

La información en esta publicación se obtuvo de Clinical Practice Guideline on Cardiac Rehabilitation. La guía fue escrita por un panel de expertos del sector no gubernamental patrocinados por la Agency for Health Care Policy and Research (AHCPR), una agencia del Servicio de Salud Pública de los Estados Unidos. También cooperó en esta publicación el National Heart, Lung and Blood Institute. Existen y se están desarrollando otras Guías para pacientes en inglés y español sobre diversos problemas de salud.

Existen otras tres publicaciones para el paciente de la AHCPR para las personas interesadas en participar en servicios de rehabilitación cardíaca:

- La angina de pecho inestable (en español) (AHCPR Pub No. 94-0605)
- La insuficiencia cardíaca (en español) (AHCPR Pub No. 94-0515)
- La depresión: Existen tratamientos (en español) (AHCPR Pub No. 94-0554)

Para más información sobre las Guías para el paciente o para recibir copias de esta publicación, llame gratis al 1-800-358-9295, o escriba a: AHCPR Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907