# Tratamientos para las llagas por contacto

## ¿Qué son las llagas por contacto?

Las llagas (úlceras) por contacto resultan de una presíon prolongada que causa lesiones de la piel y los tejidos bajo está. Si una persona permanece sentada o acostada en la misma posición por un período prolongado, la presíon constante en la piel oprime pequeños vasos sanguíneos (venas) que normalmente llevan oxígeno y nutrientes a los tejidos. Cuando la presíon no permite que lleguen el oxígeno y los nutrientes por demasiado tiempo, el tejido se muere y esto es lo que forma una llaga.

Las llagas por contacto, también conocidas como escaras por decúbito, varían en gravedad dependiendo del grado de daño a la piel y al tejido. El daño puede variar desde un cambio en el color de la piel sin lesión externa (Grado I), hasta daño severo, con lesiones profundas que llegan hasta el músculo o el hueso (Grado IV), vea el Dibujo 1 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf1.gif). En los pacientes de piel clara, una llaga de Grado I puede hacer que la piel cambie a un color morado oscuro o rojo, que no palidece bajo la presíon por el contacto de un dedo. En las personas de piel oscura, la piel puede ponerse más oscura de lo normal. El área afectada puede sentirse más caliente que el tejido que la rodea.

## El propósito de esta publicación

Las llagas por contacto son problemas serios y no se deben ignorar. Con el tratamiento apropiado, la mayoría de estas lesiones sanarán. La curación depende de muchos elementos: La salud general del paciente, su dieta, aliviar la presíon en el área de la úlcera, y mantener la llaga limpia y con un aposíto (vendaje).

Esta publicación les ayudará a usted y la persona encargada de su cuidado a tratar las llagas por contacto. También le proporciona información sobre la prevención de las llagas.

Muestre esta publicación a los miembros de su familia y las personas a cargo de su cuidado. En cooperación con los profesionales de la salud a cargo de su cuidado y siguiendo las recomendaciones que se dan a continuación, podrán proporcionar tratamiento adecuado para las llagas por contacto y prevenir que aparezcan otras.

La publicación presenta pasos específicos para ayudar a que sane una llaga por contacto. Aunque no todos los pasos son relevantes para todos los pacientes, es importante que usted:

- Aprenda a prevenir y tratar las llagas por contacto.
- Haga preguntas en caso que no entienda algo.
- Exprese sus necesidades y preocupaciones.
- Sepa cuáles son las mejores opciones en su caso.
- Desempeñe un papel activo en su cuidado de salud.

## Tratamientos

El tratamiento de las llagas por contacto es un esfuerzo del grupo de profesionales de la salud a cargo de su cuidado, quienes desarrollarán con usted un plan de tratamiento. Este grupo puede incluir médicos, enfermeras, especialistas en dietética (alimentación), trabajadores sociales, farmaceutas, y terapistas ocupacionales y fisícos. Los dos elementos más importantes de este grupo, sin embargo, son usted y la persona a cargo de su cuidado díario. Es importante que comparta cualquier pregunta o preocupación con los profesionales a cargo de su cuidado.

### Su papel

Usted y la persona a cargo de su cuidado tienen que:

- Saber sus propias responsabilidades dentro del plan de tratamiento.
- Aprender a desempeñar las tareas del tratamiento.
- Saber lo que le tiene que reportar al médico o a la enfermera.
- Saber evaluar si el tratamiento está funcionando.
- Ayudar a cambiar el curso del tratamiento si esto es necesario.
- Saber las preguntas que tiene que hacer.
- Recibir respuestas que pueda comprender.

### El plan de tratamiento

Para desarrollar un plan que responda a sus necesidades, el médico o la enfermera necesita saber lo siguiente:

- Su estado general de salud.
- Las enfermedades que podrían hacer más lenta su curación (como la diabetes o el endurecimiento de las arterias).
- Los medicamentos que toma con o sin receta médica.
- El apoyo emocional y físico con el que cuenta por parte de su familia, amigos y otros.

El médico o la enfermera le hará un examen físico y examinará la llaga para decidir cómo tratarla. Si ya ha tenido una llaga por contacto en el pasado, dígale lo que ha ayudado y lo que no ha ayudado a sanarla.

Su bienestar emocional también es importante, así es que debe hablar con su médico sobre sus tensiones emocionales y sus creencias en cuanto a los tratamientos y las enfermedades. Esto le permitirá desarrollar un plan de tratamiento que responda a sus necesidades individuales.

El plan de tratamiento se desarrollará basándose en el examen físico, sus antecedentes de salud, sus circunstancias personales, y la condición de la llaga misma. El plan incluirá instrucciones específicas para:

- Aliviar la presíon sobre la llaga.
- El cuidado de la lesión de la llaga, su limpieza, quitar el tejido muerto y otros desechos, y colocar aposítos y vendajes en el área para proteger la lesión mientras sana.
- Ayudar a su curación asegurándose que coma alimentos con suficientes calorías, proteínas, vitaminas y minerales.

### Nota para el proveedor de cuidado

A pesar que el paciente debe desempeñar el papel más activo posible en su propio cuidado de salud, es probable que sea usted quien proporcione la mayoría de este cuidado. Si tiene preguntas o problemas, pida ayuda. Llame a los doctores, enfermeras, y otros profesionales de la salud para pedir su asistencia y apoyo.

Recuerde que los pacientes que tienen que permanecer en una silla o en una cama por períodos largos de tiempo no tienen que padecer de llagas por contacto, ya que estas se pueden prevenir. Las llagas ya existentes se pueden curar.

## Cómo ayudar a sanar las llagas por contacto

La curación de las llagas por contacto depende de tres pasos: Aliviar la presíon sobre la llaga, cuidar la lesión, y una nutrición adecuada.

### Aliviar la presíon

Las llagas por contacto se forman cuando hay presíon prolongada en ciertas áreas del cuerpo. Los períodos largos de presíon sin alivio pueden empeorar o hacer más lenta la curación una vez que se ha formado una lesión. Aliviar la presíon sobre la llaga es el primer paso para la curación.

Las llagas por contacto se forman en las áreas del cuerpo en donde los huesos causan presíon en la piel (como en las caderas y los talones), que son áreas que apoyan el peso del cuerpo por períodos prolongados. El Dibujo 2 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf2.gif) muestra ÒLos puntos de presíonÓ del cuerpo en donde frecuentemente se forman las llagas.

Para reducir o aliviar la presíon puede:

- Usar superficies de soporte especiales en donde apoyar su cuerpo.
- Colocar su cuerpo en ciertas posiciones.
- Cambiar de posícion frecuentemente.

#### Superficies de soporte

Estas incluyen camas especiales, colchones, cubiertas para colchón, o cojines para asientos que apoyan su cuerpo cuando está en la cama o en una silla. Estas superficies reducen o alivian el grado de la presíon y, al hacerlo, ayudan a sanar y prevenir las llagas por contacto.

Puede obtener diferentes tipos de superficies de soporte. La más adecuada depende de su salud, si puede cambiar de posícion, el tamaño de su cuerpo, y la condición de la llaga. Usted y el médico o la enfermera pueden elegir la más apropiada.

Una manera de revisar si la superficie de soporte alivia la presíon lo suficiente es que el proveedor de cuidado coloque la mano bajo el paciente (Dibujo 3 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf3.gif)). Coloque su mano bajo la superficie de soporte, bajo el punto de presión, con la palma hacia arriba y los dedos en una posición recta. Si hay menos de una pulgada del material de la superficie de soporte entre el punto de presión en el cuerpo del paciente y su mano, la superficie no está proporcionando suficiente apoyo. Si este es el caso, el médico o la enfermera le dará otras sugerencias para superficies de soporte.

Los proveedores de cuidado deben saber que las llagas por contacto son frecuentemente dolorosas y que revisar la superficie de soporte puede aumentar el dolor. Deben preguntar al paciente si pueden hacer la revisión y hacerla tan suavemente como sea posible.

#### Posiciones adecuadas del cuerpo

Su posición es importante para aliviar la presión sobre la llaga y para prevenir otras llagas. Necesita cambiar de posición ya sea en la cama o en una silla.

En la cama. Siga estas instrucciones:

- No se apoye en la llaga. Use cojines o almohadas de hule espuma para aliviar la presión sobre la llaga, como se muestra en el Dibujo 4 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf4.gif).
- Cambie de posición por lo menos cada 2 horas.
- No se apoye directamente en el hueso de su cadera cuando se acueste de lado. Una inclinación de aproximadamente 30 grados es más adecuada (vea el Dibujo 4 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf4.gif)).
- Cuando se acueste boca arriba, mantenga sus talones alejados de la cama. Coloque un cojín delgado de hule espuma o una almohada bajo sus piernas; de la pantorrilla al tobillo (Dibujo 5 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf5.gif)). El cojín o almohada debe elevar los talones sólo lo suficiente para poder pasar una hoja de papel entre los pies y la cama. No coloque el cojín o la almohada directamente detrás de la rodilla; ya que esto puede reducir la circulación de la sangre hacia la parte inferior de la pierna.
- No use cojines en forma de anillo, ya que reducen el flujo de la sangre al tejido.
- Use cojines o almohadas de hule espuma entre sus rodillas y tobillos para evitar que se toquen uno a otro.
- Levante la cabecera de la cama lo menos posible. Elévela no más de 30 grados de la posición horizontal (plana) (Dibujo 6 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf6.gif)). Si tiene otros problemas, tales como problemas respiratorios, que se mejoran cuando se incorpora, hable con el médico sobre las mejores posiciones para su caso.
- Permanezca erguido mientras come, para evitar ahogarse. La cabecera de la cama se puede volver a reclinar una hora después de la comida.

En una silla o silla de ruedas. Cuando se siente, tiene que poder mantener una posición erguida y recta (Dibujo 7 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf7.gif)). Una buena postura le ayudará a moverse con más facilidad y así prevenir llagas.

Dependiendo de sus necesidades individuales, use cojines diseñados para aliviar la presión en las superficies de asiento. Incluso cuando la presión se pueda aliviar con cojines, debe de cambiar de posición por lo menos una vez cada hora. Recuerde:

- Evite sentarse directamente en una llaga por contacto.
- Mantenga la parte superior de sus muslos en una posición horizontal y los tobillos en una posición cómoda y ÒneutralÓ ya sea sobre el piso o los pedales para los pies de la silla de ruedas (Dibujo 7 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf7.gif)). Coloque sus codos y antebrazos en los brazos de la silla.
- Si no puede moverse por sí mismo, trate que alguien le ayude a cambiar de posición por lo menos cada hora. Si se puede mover usted mismo, hágalo cada 15 minutos.
- Si su posición en una silla no se puede cambiar, haga que alguien le ayude a regresar a la cama para poder cambiar de posición.
- No use cojines en forma de anillo; ya que reducen la circulación de la sangre al tejido.

#### Cambiar de posición

Cambie la posición de su cuerpo frecuentemente--por lo menos cada hora cuando esté en una silla y por lo menos cada dos horas cuando esté en la cama. Un horario de cambio de posición por escrito o un reloj que indique las posiciones en las horas apropiadas, puede ayudarle y a su proveedor de cuidado a recordar cambiar de posición, y la hora a la que deben hacerlo. Probablemente un reloj de campana, como los que se usan en la cocina, también sea útil.

Asegúrese que su plan funcione en su caso. Debe tomar en consideración el estado de su piel, sus necesidades y preferencias personales, y su nivel de comodidad.

### Cuidado de la lesión de la llaga

El segundo paso de la curación adecuada de las llagas por contacto es el cuidado de la lesión. Los tres aspectos de éste son:

- Limpieza.
- Quitar el tejido muerto y otros desechos.
- Colocar apósitos y vendar la lesión de la llaga.

El cuidado para la lesión de la llaga se resume en la Tabla 1 en las páginas 12 y 13.

Tabla 1. Pasos básicos de cuidado de las llagas por contacto

Tarea | Pasos específicos
Preparación | 1. Lávese las manos con agua y jabón.; 2. Busque los materiales necesarios: La solución salina, equipo para irrigar (jeringa u otro instrumento, vasija, una bolsa de plástico grande); apósito; cinta adhesiva; guantes de plástico desechables; una bolsita plástica pequeña; una toallá, lentes protectores, lentes, y delantal de plástico (opcional).; 3. Coloque al paciente en una posición cómoda.; 4. Coloque una bolsa de plástico grande sobre las sábanas para que no se ensucien.
Quite el apósito viejo | 1. Coloque su mano dentro de una bolsa de plástico pequeña (vea el Dibujo 8) (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf8.gif).; 2. Tome el apósito viejo con la mano dentro de la bolsa y retírelo de la piel.; 3. Voltee la bolsa al revés para cubrir el apósito sucio.; 4. Cierre la bolsa bien antes de desecharla.
Irrigue la llaga | 1. Póngase unos guantes de plástico desechables. (Use lentes o lentes de plástico de protección y un babero si es que el líquido de la herida pudiera salpicar.); 2. Llene la jeringa u otro instrumento de irrigación con solución salina.; 3. Coloque la vasija debajo de la llaga para recolectar el liquido que escurra.; 4. Sostenga el irrigador de 1 a 6 pulgadas de la llaga e irrigue suavemente con solución salina.; 5. Use suficiente fuerza en la irrigación para despegar el tejido muerto y la supuración; pero no dañe el tejido nuevo.; 6. Quite la vasija sin derramar el líquido.; 7. Seque la piel alrededor de la llaga llaga con toques suaves de una toalla limpia.; 8. Después de evaluar la llaga y volver a vendarla, quítese los guantes, volteandolos al reves y disponga de ellos en una forma adecuada.
Evalúe | 1. Evalúe la curación. Conforme se alivie, la llaga disminuirá de tamaño lentamente y drenará menos. El tejido nuevo en el fondo de la llaga es de color rosa o rojo y apariencia bultosa y brillosa. No dañe este tejido.; 2. Diga al médico o enfermera si la llaga es más grande, drena más, se infecta, o no hay señas de alivio en 2 a 4 semanas..
Coloque un apósito en la llaga | Siguiendo las instrucciones del médico o la enfermera, coloque un apósito (vendaje de gasa) limpio sobre la llaga. Recuerde:; 1. Use el apósito sólo una vez.; 2. Mantenga los apósitos en la envoltura original, o en otro tipo de envoltura plástica cerrada.; 3. Guarde los apósitos en un lugar seco y limpio.; 4. Deseche todo el paquete de apósitos si se mojan, contaminan, o ensucian.; 5. Lávese las manos antes de tocar apósitos limpios.; 6. No vuelva a tocar el contenido del paquete de apósitos después de haber tocado la lesión.

Usted debe saber las instrucciones sobre el cuidado de la llaga, incluso si su proveedor de cuidado siempre se encarga de hacer las curaciónes. Si usted sabe sobre esto, podrá tomar las decisiones adecuadas en cuanto a su cuidado.

#### 1. Limpiar la llaga

Las llagas por contacto sanan mejor si están limpias. No deben tener tejido muerto (que se ve como una costra), demasiada secreción, u otros desechos. Si es así, el proceso de curación se hace más lento y existe el riesgo de una infección.

El médico o la enfermera les mostrarán a usted y la persona que lo cuida la manera de limpiar y/o enjuagar la llaga. Tiene que limpiar la lesión cada vez que cambie el apósito.

Limpiar la llaga normalmente incluye el "irrigarla" (humedecerla). Los tejidos o desechos sueltos también se pueden quitar con un pedazo de gasa. Es importante que use el equipo y métodos adecuados para limpiar la llaga. Cuando el tejido está sanando, se le puede lastimar si se usa demasiada fuerza cuando se le enjuaga y, por otro lado, si no se usa la suficiente fuerza al enjuagar, puede ser que no se limpie la llaga correctamente.

Sólo use las soluciones de limpieza que recomiende el médico o la enfermera, normalmente la solución salina es lo mejor para enjuagar la llaga. La solución salina se puede comprar en la farmacia o se puede hacer en casa (Tabla 2).

Advertencia: A veces el agua se contamina. Si el departamento de salud local da una advertencia sobre el agua para beber, tiene que comprar la solución salina en la farmacia, o usar agua embotellada para hacerla.

Tabla 2. Receta para hacer solución salina

1. Use un galón de agua destilada, o hierva un galón de agua de la llave por 5 minutos. No use agua de pozo o de mar.
2. Agregue 8 cucharaditas de sal de mesa al agua hervida o destilada.
3. Mezcle la solución hasta que se disuelva la sal completamente. Asegúrese que el recipiente en que guardará la solución y el instrumento con el que la mezcle estén limpios (hervidos).
Nota: Enfríela a la temperatura ambiente antes de usarla. A esta temperatura, y en un recipiente de plástico o de vidrio bien cerrado, la solución se puede guardar por una semana.

No use antisépticos como el agua oxigenada y el yodo. Estos pueden dañar el tejido sensible y evitar que la llaga sane.

Los métodos de limpieza son eficaces para mantener las llagas por contacto limpias. Sin embargo, en algunos casos, se requerirán otros métodos para remover el tejido muerto de la lesión.

#### 2. Quitar tejidos muertos y otros desechos

El tejido muerto en la llaga por contacto puede hacer más lenta la curación y puede causar infección. Quitarlo frecuentemente es doloroso, así es que probablemente deseará tomar un medicamento contra el dolor de 30 a 60 minutos antes que realicen la curación.

Bajo la supervisión de un médico, el tejido muerto y otros desechos se pueden quitar de varias maneras:

- Enjuagando (para quitar el desecho con agua).
- Apósitos húmedos/secos. En este método especial, se colocan apósitos mojados sobre la lesión y se les deja secar. El tejido muerto y los desechos se quitan cuando se quita el aposito seco. Se usa este método únicamente para quitar el tejido muerto, nunca se usa en una lesión limpia.
- Medicamentos enzímicos que sólo disuelven los tejidos muertos.
- Ciertos apósitos especiales se dejan en la piel por varios días y éstos ayudan a las enzimas naturales del cuerpo a disolver lentamente los tejidos muertos. Este método no se debe usar si la llaga está infectada. Si es asi se debe usar un método rápido para quitar el tejido muerto y otros desechos en las llagas infectadas.

El médico y otros profesionales capacitados pueden usar instrumentos quirúrgicos para quitar el tejido muerto de la piel.

Dependiendo de la salud general del paciente y la condición de la llaga, el médico o la enfermera recomendarán el mejor método para quitar el tejido muerto en cada caso.

#### 3. Elegir y usar los apósitos

Elegir el apósito adecuado es importante para el cuidado de una lesión. El médico o la enfermera considerarán la ubicación y condición de la llaga cuando recomienden un tipo de apósito.

Los más comunes son la gasa (humedecida con solución salina), la tela plástica (muy delgada y transparente), y el hidrocoloide (que retiene humedad y oxígeno). Las gasas se tienen que humedecer frecuentemente con solución salina y se tienen que cambiar por lo menos diariamente. Si no se mantienen húmedas, el tejido nuevo se quitará al mismo tiempo que se retire el apósito.

A menos que haya una infección, la tela plástica y el hidrocoloide se pueden dejar en la piel por varios días, para ayudarla a mantener su humedad natural.

La selección del apósito depende de:

- El tipo de material más conducente a la curación.
- La frecuencia con la que se tiene que cambiar el apósito.
- Si existe infección en la llaga.

Por lo general, el apósito debe mantener la lesión húmeda y el tejido alrededor de ella seco, pero conforme la llaga sane, puede ser necesario cambiar el tipo de apósito.

#### Cómo cuidar y guardar los apósitos

Generalmente se pueden usar apósitos limpios (no necesariamente estériles), siempre y cuando se mantengan secos y limpios. No existe evidencia que indique que usar apósitos estériles es mejor que usar apósitos limpios. Sin embargo, puede haber contaminación entre pacientes en ámbitos como hospitales y asilos de ancianos. Cuando se usan en instituciones, se deben seguir cuidadosamente ciertos procedimientos para evitar la contaminación entre pacientes.

En el hogar también se pueden usar apósitos limpios. Siga cuidadosamente las siguientes instrucciones para guardarlos, cuidarlos y cambiarlos.

Para mantener los apósitos limpios y secos:

- Guárdelos en su envoltura original (o en otras envolturas plásticas que se puedan cerrar) en un lugar seco y limpio.
- Lávese las manos con jabón y agua antes de tocar los apósitos limpios.
- Saque el apósito de la envoltura sólo cuando lo vaya a usar.
- No toque los apósitos del paquete una vez que haya tocado la llaga.
- Deseche el paquete entero si cualquiera de los apósitos se han mojado o ensuciado.

Para cambiar el apósito. Pida al médico o la enfermera que le muestre cómo hacerlo. Si es posible, deje que el médico lo vea hacerlo por lo menos una vez.

Pida instrucciones por escrito si las necesita. Si tiene preguntas o problemas en cuanto a cómo hacerlo, hable con el médico o la enfermera.

Lávese las manos con agua y jabón antes y después de cambiar el apósito. Use cada apósito sólo una vez. Debe revisar que el apósito permanezca en su lugar al cambiar de posiciones. Después de cambiar el apósito, debe asegurarse de desecharlo de tal manera que evite que se dispersen gérmenes.

Usar bolsas de plástico para retirar los apósitos. Una bolsa de plástico pequeña (como las que se usan para guardar emparedados) se puede usar para retirar el apósito de la llaga (Dibujo 8 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf8.gif)). Cierre la bolsa antes de tirarla. Si usa guantes, tírelos después de cada curación.

### Una alimentación adecuada

Una alimentación adecuada es el tercer paso para la curación. Comer una dieta equilibrada le ayudará a que sanen las llagas y a prevenir que se formen llagas nuevas.

Usted y su médico, especialista en dietética o enfermera deben hablar sobre otras condiciones médicas que tenga (tales como la diabetes o problemas del riñon) antes de diseñar una dieta especial.

Pésese una vez a la semana. Si nota que no puede ingerir suficiente comida para mantenerse en peso, o nota un aumento o reducción de peso súbitos, probablemente necesitará una dieta especial o suplementos de vitaminas. Probablemente necesita más calorías cómo parte de una dieta equilibrada.

Dígale al médico o la enfermera sobre sus cambios de peso. Un aumento o reducción de 10 libras de peso en un período de 6 meses, sin haberlo intentado, tiene que ser evaluado por un médico.

## El dolor y las infecciones

Incluso si cuida su llaga adecuadamente, pueden surgir problemas tales como una infección o el dolor. El dolor le puede impedir moverse o participar en su cuidado, y la infección puede hacer más lenta la curación.

### El control del dolor

Dígale al médico o la enfermera si tiene dolor cerca o en el lugar de la llaga. Cubrir la llaga con un apósito o cambiar de posición podría ayudar a reducir el dolor.

Si tiene dolor cuando le limpian o cambian el apósito, puede tomar medicina ya sea de receta médica o que puede comprar sin receta. Tómela entre 30 y 60 minutos antes de la curación y hable con el médico o la enfermera si la medicina no le ayuda.

### Tratamiento para la infección

Si se presenta una infección, la llaga puede tardar más en sanar. La infección de la llaga se puede expandir al tejido adyacente (celulitis), al hueso bajo la llaga (osteomielitis), o a todo el cuerpo (sepsis). Estas son complicaciones serias que requieren atención médica inmediata. Si nota cualquiera de los síntomas de infección de la Tabla 3, llame a su médico de inmediato.

Tabla 3. Síntomas de una infección

Llaga infectada | Infección generalizada
Secreción espesa verde o amarillenta. | Fiebre o escalofríos.
Mal olor. | Debilidad.
Tejido alrededor de la llaga caliente o rojizo. | Confusión mental o dificultad para concentrarse.
Sensibilidad al tacto en el área alrededor de la llaga. | Latidos acelerados del corazón.
Inflamación.

## Revise su progreso

El médico o la enfermera debe revisar su llaga regularmente, con la frecuencia indicada de acuerdo a su progreso. Normalmente, una llaga por contacto se debe revisar una vez a la semana.

### El examen de la llaga

El momento mejor para revisar la llaga es después que se ha limpiado. Debe notar señas de mejoría en 2 a 4 semanas y éstas incluyen que la llaga haya disminuido de tamaño o profundidad y que tenga menos secreción. Las llagas infectadas pueden llevarse más tiempo en sanar.

### Síntomas que debe reportar

Diga al médico o la enfermera si:

- La llaga es más grande o profunda.
- Si fluye más secreción de la llaga.
- Si no empieza a sanar en 2 a 4 semanas.
- Si ve síntomas de infección (vea la Tabla 3).

También reporte:

- Si no puede comer una alimentación equilibrada.
- Si tiene cualquier problema para seguir el plan de tratamiento.
- Si su estado de salud general empeora.

### Cambiar el plan de tratamiento

Si se presentan cualesquiera de estos síntomas, es probable que tengan que cambiar el plan de tratamiento. Dependiendo de sus necesidades, puede que se cambie lo siguiente:

- Superficies de soporte.
- La frecuencia con la que cambia de posición al estar en la cama o sentado.
- Los métodos para limpiar la llaga y quitar el tejido muerto.
- El tipo de apósito.
- Su alimentación.
- El tratamiento contra las infecciones.

### Otras opciones de tratamiento

Si no sanan las llagas, el médico podría recomendar la estimulación electrónica celular, en la que se usa una pequeña corriente eléctrica para ayudar a sanar la llaga. Este tratamiento es relativamente nuevo, así es que es posible que no existan el equipo o personal capacitado para realizarlo.

Si la llaga es grande o profunda o no sana, es probable que sea necesario realizar una operación para reparar el tejido dañado. Usted y el médico deben hablar sobre esta opción.

## El cuidado de la piel sana

Tener la piel sana es importante en la prevención de las llagas por contacto, ya que ésta tiene menor posibilidad de lesionarse y sana más rápidamente que la piel que está en mala condición.

Puede prevenir nuevas llagas al mismo tiempo que cura las que ya tiene. Para mejorar la salud de su piel:

- Báñese cuando sea necesario para estar limpio y cómodo.
- Use jabón suave y agua tibia (no caliente).
- Use cremas humectantes (como cremas para la piel) para evitar que se reseque la piel.

Examine su piel por lo menos una vez al día para ver si tiene áreas enrojecidas u otros camios del color de la piel, o alguna llaga. Preste especial atención a los puntos de presión en donde se podrían formar llagas (Dibujo 2 (http://text.nlm.nih.gov/ahcpr/put/ft-ww/putsf2.gif)).

Los problemas de la piel también pueden resultar de problemas de control de la orina o del excremento (incontinencia urinaria o fecal). Si tiene estos problemas, pida consejos de su médico o enfermera. Si no se puede controlar la pérdida:

- Limpie la piel en cuanto se ensucie.
- Use una crema o unguento protector para evitar que se moje la piel.
- Use toallas sanitarias y/o ropa interior especial para absorber la humedad y proteger la piel.

Para obtener información más detallada sobre la prevención de las llagas por contacto en español, solicite la publicación de AHCPR titulada La prevención de las llagas por contacto. Guía para el paciente. Para solicitarla, vea la página 23.

## Para obtener más información

La información en esta publicación se obtuvo de Treatment of Pressure Ulcers. Clinical Practice Guideline, Number 15. La guía fue escrita por un panel de expertos del sector no gubernamental patrocinado por la Agency for Health Care Policy and Research (AHCPR), una agencia del Servicio de Salud Pública de los Estados Unidos. Existen y se están desarrollando otras Guías para pacientes en inglés y español sobre diversos problemas de salud.

Existen otras cuatro publicaciones para el paciente de la AHCPR que pueden ser de interés para las personas que tienen riesgo de padecer o padecen de llagas por contacto:

La prevención de las llagas por contacto: guía para el paciente (en español) que proporciona detalles sobre la prevención de esta condición (AHCPR Publication No. 93-0014).

La incontinencia urinaria en los adultos: guía para el paciente (en español) que describe el por qué de este problema y cómo prevenir las llagas por contacto si padece de esta condición (AHCPR Publication No. 92-0089).

El control del dolor después de una operación: guía para el paciente (en español) que describe diferentes tipos de tratamiento contra el dolor y cómo cooperar con médicos y enfermeras para prevenir o aliviar el dolor (AHCPR Publication No. 92-0068).

Existen tratamientos para la depresión: guía para el paciente (en español) que presenta información sobre los desórdenes depresivos mayores, que se pueden tratar con éxito con la ayuda de profesionales de la salud (AHCPR Publication No. 93-0554).

Para más información sobre las Guías para el paciente o para recibir copias de esta publicación, llame gratis al 1-800-358-9295, o escriba a:

- AHCPR Publications Clearinghouse
- P.O. Box 8547
- Silver Spring, Maryland 20907

## Desempeñe un papel activo en su cuidado

Si entiende las conceptos básicos sobre cómo aliviar la presión sobre la llaga, el cuidado de la lesión, y la buena alimentación, usted puede tomar los pasos necesarios para sanar las llagas por contacto y prevenir que aparezcan otras. No todos los pasos son apropiados para todos los pacientes. El mejor programa depende de sus necesidades y la condición de las llagas.

Asegúrese de:

- Hacer preguntas.
- Explicar sus necesidades, deseos y preocupaciones.
- Entender lo que se tiene que hacer y por qué.
- Lo que es mejor en su caso. Hable con el médico sobre las maneras de prevenir y tratar las llagas por contacto en el hogar, el hospital, o el asilo de ancianos.

Desempeñe un papel activo en su cuidado de salud.

## Otros recursos

Las siguentes organizaciones ofrecen una variedad de recursos a las personas que padecen o cuidan de alguien que padece de llagas por contacto.

Publicaciones e información para pacientes, proveedores de cuidado, y familiares que proporcionan cuidado en el hogar.

- National Pressure Ulcer Advisory Panel (NPUAP)
- SUNY at Buffalo
- Beck Hall
- 3435 Main Street
- Buffalo, NY 14214
- (716) 881-3558

Para encontrar enfermeras en su área que son especialistas en terapia de enterostomía:

- Wound Ostomy and Continence Nurses Society (WOCN)
- (antes conocida como International Association of Enterostomal Therapy)
- 27241 La Paz Road
- Suite 121
- Laguna Niguel, CA 92656
- (714) 476-0268

Información sobre nutrición

- National Center for Nutrition and Dietetics (NCND)

Línea gratuita de información al público: (800) 366-1655

## Dibujos

### Grados de las llagas por contacto

[image]

### Puntos de presión

[image]

### Revisión manual para evaluar la eficacia de la superficie de soporte

[image]

### La mejor posición cuando se acuesté de lado

[image]

### que los talones no toquen la cama

[image]

### Con la cabecera de la cama elevada 30 grados

[image]

### Mejor posición si se encuentra en una silla

[image]

### Uso de bolsitas de plástico para quitar los apósitos

[image]