# Healthy Weight: Foundations in Early Childhood, 2021

Healthy habits established in childhood have lifelong benefits.^ 1,2 ^ In 2021, with support from the Centers for Disease Control and Prevention (CDC) Division of Nutrition, Physical Activity and Obesity, questions about young children’s consumption of fruits, vegetables, and sugary drinks, and the time they spent playing outdoors were added to the NSCH. Together with existing questions about screen time and sleep, this brief presents the prevalence of six healthy weight behaviors among children 3-5 years in the United States (US).

## PREVALENCE OF HEALTHY WEIGHT BEHAVIORS

- In 2021, 2 in 3 (65.7%) preschool-age children ate fruit a least once a day while less than half (48.9%) ate vegetables at least once a day. The Dietary Guidelines for Americans (https://www.dietaryguidelines.gov/sites/default/files/2021-03/Dietary_Guidelines_for_Americans-2020-2025.pdf) recommend eating a variety of fruits and vegetables every day.
- Only 1 in 3 (32.6%) preschool-age children had no sugary drinks in the past week. Sugary drinks (e.g., soda, sports drinks, and fruit drinks that are not 100% juice) are not necessary in the child diet and are not a recommended component of the Dietary Guidelines for Americans.
- Only 39.9% of preschool-age children had limited screentime of 1 hour or less per weekday. The American Academy of Pediatrics (https://publications.aap.org/pediatrics/article/138/5/e20162591/60503/Media-and-Young-Minds?autologincheck=redirected) recommends limiting screentime to 1 hour per day of high-quality programming for children 2-5 years.
- 58.7% of preschool-age children played outdoors 2 or more hours per day. The Physical Activity Guidelines for Americans (https://health.gov/sites/default/files/2019-09/Physical_Activity_Guidelines_2nd_edition.pdf#page=46) recommend that children 3-5 years be physically active throughout the day.
- Similarly, 61.4% of preschool-age children slept 10 hours or more per day. The American Academy of Sleep Medicine (https://aasm.org/resources/pdf/pediatricsleepdurationconsensus.pdf) recommends children 3-5 years sleep 10-13 hours per day (including naps).

Percent of Children 3-5 Years Engaging in 5 or 6 Healthy Weight Behaviors, 2021

Bar graph: Percent of children 3 to 5 years engaging in healthy weight behaviors, 2021. Fruit 1+ times per day 65.7%, vegetables 1+ times per day 48.9%, avoid sugary drinks 0 in past week 32.6%, limited screen time ?1 hour per weekday 39.9%, outdoor play 2+ hours per day 58.7%, sleep 10+ hours per day 61.4%.

## VARIATIONS IN HEALTHY WEIGHT BEHAVIORS BY FAMILY INCOME

- As income increased, the percent of preschool-age children engaging in each healthy behavior increased.
- The largest differences by family income (30+ percentage points) were in the percent of children getting adequate sleep and avoiding sugary beverages. For example, less than half (42.7%) of children in families below poverty averaged 10 hours or more of sleep per day versus 3 out of 4 (76.5%) children with a family income of 400% or more of poverty.
- The smallest difference by family income (10 percentage points) was in the percent of children playing outdoors for 2 or more hours per day, ranging from 53.2% of children in families below poverty to 63.7% of children with a family income of 400% or more of poverty.
- Among all children 3-5 years in the US, 17.6% (2.0 million) engaged in 0 or 1 healthy behavior, 62.1% (7.0 million) engaged in 2 to 4 healthy behaviors, and 20.3% (2.3 million) engaged in 5 or 6 healthy behaviors.
- As family income increased, the number of healthy weight behaviors that children engaged in increased. For example, only 1 in 11 (9.3%) preschool-age children in poverty engaged in 5 or 6 healthy behaviors while 1 in 3 (30.7%) children in families at 400% or more of poverty engaged in 5 or 6 healthy weight behaviors.

Percent of Children 3-5 Years Engaging in Healthy Weight Behaviors by Family Income^*^, 2021

^*^Ratio of Income to Poverty Thresholds; the U.S. Census Bureau Poverty Threshold for a Family with two children and two adults was $27,479 in 2021.

Clustered bar graph: Percent of children 3 to 5 years engaging in healthy weight behaviors by family income, 2021. Fruit 1+ times per day: less than 100% of poverty 58.1%, 100-199% of poverty 58.5%, 200-399% of poverty 65.7%, 400% of poverty 75.3%. Vegetables 1+ times per day: less than 100% of poverty 42.2%, 100-199% of poverty 43.9%, 200-399% of poverty 50.2%, 400% of poverty 55.4%. Avoid sugary drinks 0 in past week: less than 100% of poverty 16.1%, 100-199% of poverty 26.8%, 200-399% of poverty 33.3%, 400% of poverty 46.7%. Limited screentime ?1 hour per weekday: less than 100% of poverty 34.5%, 100-199% of poverty 33.2%, 200-399% of poverty 39.0%, 400% of poverty 48.5%. Outdoor play 2+ hours per day: less than 100% of poverty 53.2%, 100-199% of poverty 55.4%, 200-399% of poverty 59.3%, 400% of poverty 63.7%. Sleep 10+ hours per day: less than 100% of poverty 42.7%, 100-199% of poverty 54.0%, 200-399% of poverty 63.7%, 400% of poverty 76.5%.

Percent of Children 3-5 Years Engaging in Healthy Weight Behaviors by Family Income^*^, 2021

^*^Ratio of Income to Poverty Thresholds; the U.S. Census Bureau Poverty Threshold for a Family with two children and two adults was $27,479 in 2021.

Stacked bar graph: Percent of children 3 to 5 years engaging in healthy weight behaviors by family income, 2021. Total: 0-1 healthy behaviors 17.6%, 2-4 healthy behaviors 62.1%, 5-6 healthy behaviors 20.3%. Less than 100% of poverty: 0-1 healthy behaviors 24.9%, 2-4 healthy behaviors 65.8%, 5-6 healthy behaviors 9.3%. Between 100 and 199% of poverty: 0-1 healthy behaviors 23.2%, 2-4 healthy behaviors 63.7%, 5-6 healthy behaviors 13.1%. Between 200 and 399% of poverty: 0-1 healthy behaviors 18.3%, 2-4 healthy behaviors 60.6%, 5-6 healthy behaviors 21.1%. 400% or more of poverty: 0-1 healthy behaviors 9.1%, 2-4 healthy behaviors 60.2%, 5-6 healthy behaviors 30.7%.

## STATE VARIATION IN HEALTHY WEIGHT BEHAVIORS

- The percent of preschool-age children engaging in 5 or 6 healthy behaviors varied widely by state, ranging from 7.2% in Mississippi to 48.3% in Vermont.
- Seven states had a significantly lower percent of children 3-5 years engaging in 5 or 6 healthy weight behaviors than in the US overall: Mississippi (7.2%), Oklahoma (8.8%), Louisiana (11.3%), Alabama (11.4%), Arizona (11.4%), Texas (12.5%), and Georgia (13.3%).
- Seven states had a signicantly higher percent of children 3-5 years engaging in 5 or 6 healthy weight behaviors than in the U.S. overall: Vermont (48.3%), New Hampshire (39.1%), Maine (35.9%), Minnesota (35.2%), Wyoming (32.0%), Oregon (29.7%), and Colorado (28.9%).

Percent of Children 3-5 Years Engaging in 5 or 6 Healthy Weight Behaviors, 2021

Map of the United States: Percent of children 3 to 5 years engaging in five or six healthy weight behaviors, 2021. U S rate 20.3%, Alabama 11.4%, Alaska 27.3%, Arizona 11.4%, Arkansa 14.3%, California 26.7%, Colorado 28.9%, Connecticut 19.6%, Delaware 15.6%, District of Columbia 28.6%, Florida 15.7%, Georgia 13.3%, Hawaii 22.0%, Idaho 15.6%, Illinois 23.0%, Indiana 14.9%, Iowa19.6%, Kansas 22.8%, Kentucky 20.5%, Louisiana 11.3%, Maine 35.9%, Maryland 24.6%, Massachusetts 21.4%, Michigan 25.8%, Minnesota 35.2%, Mississippi 7.2%, Missouri 19.0%, Montana 29.5%, Nebraska 19.6%, Nevada 13.8%, New Hampshire 39.1%, New Jersey 20.5%, New Mexico 23.5%, New York 18.8%, North Carolina 20.1%, North Dakota 22.4%, Ohio 23.4%, Oklahoma 8.8%, Oregon 29.7%, Pennsylvania 21.3%, Rhode Island 21.6%, South Carolina 25.1%, South Dakota 22.4%, Tennessee 18.5%, Texas 12.5%, Utah 18.1%, Vermont 48.3%, Virginia 20.6%, Washington 26.1%, West Virginia 32.0%, Wisconsin 24.2%, Wyoming 32.0%.

## DATA NOTE

In 2021, parents completed questionnaires for 12,002 children ages 3-5 years. Estimates presented in this brief are weighted to represent children living in U.S. households and children living in each state. Combining multiple years of data enables more reliable estimates, especially for smaller populations. Survey questions about nutrition and outdoor play were first added to the 2021 NSCH. Therefore, it is not yet possible to combine data from multiple years, conduct comparisons to prior years, or examine trends over time for those questions. For details about NSCH questions for young children (0-5 years), middle-age children (6-11 years), and adolescents (12-17 years), visit MCHB’s NSCH webpage (https://mchb.hrsa.gov/national-survey-childrens-health-questionnaires-datasets-supporting-documents).

### ABOUT THE NSCH

The Health Resources and Services Administration’s (HRSA) Maternal and Child Health Bureau (MCHB) funds and directs the National Survey of Children’s Health (NSCH), the largest national and state-level survey on the health and health care needs of children 0-17 years, their families, and their communities.

### HEALTHY WEIGHT TOPICS

The NSCH includes a variety of topics related to healthy weight:

- Weight status and concerns (0-17 years)
- Infant feeding (0-5 years)
- Consumption of fruits & vegetables (1-5 years)
- Consumption of sugary drinks (1-5 years)
- Amount of physical activity (3-17 years)
- Frequency of family meals (0-17 years)
- Amount of screen time (0-17 years)
- Amount of sleep (0-17 years)
- Household food sufficiency (0-17 years)
- Household difficulty covering the basics like food or housing (0-17 years)
- Household receipt of support for food or basic needs (0-17 years)
- Neighborhood amenities for physical activity (0-17 years)
- Eating and weight-related behaviors (6-17 years) will be available in October 2023

1 Centers for Disease Control and Prevention. Healthy Weight Nutrition, and Physical Activity (https://www.cdc.gov/healthyweight/index.html)

2 Centers for Disease Control and Prevention. Preventing Childhood Obesity: 4 Things Families Can Do (https://www.cdc.gov/nccdphp/dnpao/features/childhood-obesity/index.html)

For more information about HRSA’s Maternal and Child Health Bureau, visit mchb.hrsa.gov.

## References

U.S. Department of Agriculture and U.S. Department of Health and Human Services. Dietary Guidelines for Americans, 2020-2025. 9th Edition. December 2020. Available at www.DietaryGuidelines.gov
COUNCIL ON COMMUNICATIONS AND MEDIA, David Hill, Nusheen Ameenuddin, Yolanda (Linda) Reid Chassiakos, Corinn Cross, Jeffrey Hutchinson, Alanna Levine, Rhea Boyd, Robert Mendelson, Megan Moreno, Wendy Sue Swanson; Media and Young Minds. Pediatrics November 2016; 138 (5): e20162591. 10.1542/peds.2016-2591 27940793
U.S. Department of Health and Human Services. Physical Activity Guidelines for Americans, 2nd edition. Washington, DC: U.S. Department of Health and Human Services; 2018. Available at https://health.gov/sites/default/files/2019-09/Physical_Activity_Guidelines_2nd_edition.pdf
Paruthi S, Brooks LJ, D'Ambrosio C, Hall WA, Kotagal S, Lloyd RM, Malow BA, Maski K, Nichols C, Quan SF, Rosen CL, Troester MM, Wise MS. Recommended amount of sleep for pediatric populations: a consensus statement of the American Academy of Sleep Medicine. J Clin Sleep Med 2016;12(6):785-786. 27250809

## Data Availability

For raw data files and supporting documentation:

https://mchb.hrsa.gov/national-survey-childrens-health-questionnaires-datasets-supporting-documents

https://www.census.gov/programs-surveys/nsch/data/datasets.html

For raw data files with recoded variables and codebooks:

https://www.childhealthdata.org/help/dataset

For pre-calculated tabulations through an interactive data query:

https://www.childhealthdata.org/browse/survey