# National Survey of Children’s Health, 2019-2020

## ABOUT

The Health Resources and Services Administration’s (HRSA) Maternal and Child Health Bureau (MCHB) funds and directs the National Survey of Children’s Health (NSCH). The NSCH is the largest national- and state-level survey on the health and health care needs of children ages 0-17, their families, and their communities.

## Key Findings

### Usual Source of Preventive Care in 2019/2020

- Nearly 66 million, or 90.6%, of U.S. children 0-17 years, had a place they usually went for routine preventive care like a well-child visit.
- The proportion of children with a usual source of preventive care was highest among non-Hispanic White (94.6%) and multi-race (94.7%) children, and lowest among non-Hispanic Asian (82.5%) and Pacific Islander/Native Hawaiian (82.0%) children.
- The proportion of children with a usual source of preventive care increased as household income increased, from 82.0% at less than 100% Federal Poverty Level (FPL) to 96.2% at 400% FPL or greater.

Percent of Children with a Usual Source of Preventive Care by Race/Ethnicity & Household Income, 2019/2020

AI/AN=American Indian/Alaska Native; NH=non-Hispanic;

PI/NH=Pacific Islander/Native Hawaiian; FPL=Federal Poverty Level

### General Health Status in 2019/2020

- Nearly 66 million, or 90.4% of U.S. children 0-17 years were in excellent or very good health, as reported by a caregiver.
  - - Non-Hispanic White (93.4%) and non-Hispanic multi-race (91.2%) children were most likely to be in excellent or very good health.
  - - Non-Hispanic American Indian/Alaska Native (84.1%) and non-Hispanic Black (85.9%) children were least likely to be in excellent or very good health.
- The percent of children in excellent or very good health increased with household income, from 82.8% among those living in poverty (<100% FPL) to 95.4% among those living in households with incomes of 400% FPL or higher.
- About 1 million (1.5%) of children were reported to be in poor or fair health.

Percent of Children in Excellent or Very Good General Health by Race/Ethnicity & Household Income, 2019/2020

AI/AN=American Indian/Alaska Native; NH=non-Hispanic;

PI/NH=Pacific Islander/Native Hawaiian; FPL=Federal Poverty Level

### Trends in Emotional, Behavioral, and Developmental Disorders from 2016-2020^ 1 ^

- Among U.S. children 3-17 years, the percent of current, diagnosed emotional disorders increased from 8.0% to 10.2%. Significant increases were seen among 12-17 year olds, Hispanic, and non-Hispanic White children.
- The percent of current, diagnosed behavioral and developmental disorders remained stable among U.S. children for most age and race/Hispanic ethnicity groups: from 12.0%-12.5% and from 11.0%-12.2%, respectively.
- However, non-Hispanic White children and children 12-17 years experienced significant increases in developmental disorders: from 11.0% to 12.5% and from 11.1% to 13.1%, respectively.

Trend in Percent of Children with Emotional Disorders by Race/Ethnicity, 2016-2020

AI/AN=American Indian/Alaska Native; NH=non-Hispanic;

PI/NH=Pacific Islander/Native Hawaiian; FPL=Federal Poverty Level

Trend in Percent of Children with Emotional Disorders by Age Group, 2016-2020

## NSCH DATA COLLECTION

HRSA MCHB works with the U.S. Census Bureau to conduct the survey, oversee sampling, and produce a final data set for public use. We conduct it annually as a household survey, and the respondent is a parent or guardian with knowledge of the sampled child. Respondents complete either web-based or self-administered paper-and-pencil questionnaires. The Census Bureau selects one child per household to be the subject of the detailed age-specific questionnaire.

Data Note: In 2020, parents completed questionnaires for 42,777 children. When we combine these data with an additional 29,433 children from 2019, we have a sample of 72,210 children in 2019/2020. The 2019 and 2020 estimates for General Health Status and Usual Source of Preventive Care were not significantly different from each other and were therefore combined as 2019/2020 estimates. Combining multiple years of data enables more reliable estimates, especially for smaller subpopulations.

### TOPICS

- Family health and activities
- Health conditions and functional difficulties
- Health insurance status, type, and adequacy
- Health care service use and access
- Impact of child’s health on family
- Medical home
- Parental health
- Parental perceptions of neighborhood characteristics
- Physical and mental health
- Preventive and specialty care
- School readiness
- Transition to adult health care

### STATE OVERSAMPLE

In 2020, four states sponsored oversampling (https://www.census.gov/content/dam/Census/programs-surveys/nsch/NSCH_State_Oversample_Summary_Document.pdf) to increase state-specific sample sizes: Colorado, Nebraska, Oregon, Wisconsin.

### 2020 DATA RELEASE

Access the most recent data and supporting materials (https://mchb.hrsa.gov/data/national-surveys).

1 Emotional disorders: anxiety or depression. Behavioral disorders: attention-deficit/ hyperactivity disorder, behavioral or conduct problems, or Tourette syndrome. Developmental disorders: autism spectrum disorder, learning disability, intellectual disability, developmental delay, or speech or other language disorder

For more information about HRSA’s Maternal and Child Health Bureau, visit mchb.hrsa.gov.

## Data Availability

For raw data files and supporting documentation:

https://mchb.hrsa.gov/national-survey-childrens-health-questionnaires-datasets-supporting-documents

https://www.census.gov/programs-surveys/nsch/data/datasets.html

For raw data files with recoded variables and codebooks:

https://www.childhealthdata.org/help/dataset

For pre-calculated tabulations through an interactive data query:

https://www.childhealthdata.org/browse/survey