# Methods

## Framework

To craft a framework to evaluate home testing, we consulted experts and gathered ideas from primary studies and narrative reviews identified from literature search on home test topics.5,11–17 The operational definition of a “framework” to evaluate home testing was developed based on reviews of other frameworks. In this report, a framework is a conceptual analytic approach to evaluate the effects (i.e., benefits, harms, costs, and other effects) of the introduction of a specific home test into a disease management program. It is a suggested approach for evaluating available information. In instances where scientific data are lacking, the framework posits a number of conjectures based on professional experience, expert opinions (e.g., see the introductory statements in Walford 1985^18^), and commonsensical reasoning (e.g., some one who is blind will not be able to read a color test strip). Home test in this framework refers to any test that is not conducted in a healthcare setting. Even though the test is not conducted in a healthcare setting, our framework specifically focuses on those tests that are either prescribed or recommended (in instances where the tests have been cleared for over-the-counter use) by a healthcare provider in the specific context of continual management of a chronic disease. A home test that was neither prescribed nor recommended by a healthcare provider for a specific patient is not the focus of this proposed framework. Because the purpose of the test is to help manage a chronic disease, home testing for the purpose of making a diagnosis is not considered in this framework. We also adapted the term “chronic disease” from the term “chronic condition” as defined by the National Center for Health Statistics (i.e., conditions that are not cured once acquired and must have been present 3 months or longer). (cdc.gov/nchs/datawh/nchsdefs/healthcondition.htm#chronic, accessed 3/26/2008)

As have been mentioned in the introduction, we have developed our framework based on the model first proposed by Fryback and Thornbury.6 This framework suggests that six aspects of a home test be described and evaluated: 1) feasibility of the implementation of the test for actual home use (N.B., please note that the actual technical aspects of the test like laboratory testing reliability and stability are not addressed in this framework, it is assumed those aspects have been evaluated and the specific test has been cleared by the FDA), 2) diagnostic accuracy of the test (How well does the test perform at identifying patients with disease and without disease when use in a home setting?), 3) impact of the test on decision making (either by the physician or by the patient or by both), 4) impact of the test on changes in actual management, 5) impact of the test on health outcomes, and 6) impact of the test on societal outcomes (e.g., disease burden, cost).

## Home tests for hemoglobin A1c and cholesterol

We searched Medline and the Cochrane CENTRAL Register of Controlled Trials for English-language studies on the home use of hemoglobin A1c (HbA1c) and cholesterol testing. Key words to identify home test, ambulatory test, or point-of-care testing were searched and crossed with key words to identify HbA1c, diabetes, cholesterol, or dyslipidemia. The complete search strategy is described in Appendix A. We also examined reviews for potentially relevant citations. The populations of interest were adults with type 1 and 2 diabetes or dyslipidemia. Tests considered were any tests marketed for home use with the express purpose of measuring either the glycosylated hemoglobin (HbA1c) or cholesterol. Because of the low yield from our abstract screening (see Results),we also contacted the manufacturers of the home tests for HbA1c and cholesterol via email, or telephone for additional published or unpublished information. In all cases, we either did not receive a reply, or the contact email provided was invalid. When contacted by telephone, the company representatives were not able to provide assistance, nor were they able to direct us to a department that could provide us with helpful information.

## Horizon scan

We first consulted experts to identify potential tests amenable to home use, then we conducted a grey literature search to answer questions concerning the currently available home tests by examining various commercial and government websites. According to the Fourth International Conference on Grey Literature in Washington, DC, in October 1999, grey literature was defined as: "That which is produced on all levels of government, academics, business and industry in print and electronic formats, but which is not controlled by commercial publishers." Grey literature can include, but is not limited to; reports, memoranda, conference proceedings, standards, technical documentation, government documents, and in this case also includes information retrieved from commercial manufacturer and distributor websites.

For the first step in collecting data for the horizon scan grey literature, we utilized the “Google” search engine that listed home testing devices which are used for the management of chronic disease. The grey literature search is complicated due to the nature of the Google search engine. It is very sensitive but not very specific; there are hundreds of repeat hits, and even more results that have little or no relation to the keyword. Also, the same key word may be searched the following day, but the results will always differ, and therefore, duplicating a web-based grey literature search is not possible. We decided the most efficient way to proceed was to create a list of chronic diseases of interest, then search for devices used by patients with these specific diseases. The chronic diseases included: diabetes mellitus, hyper- and hypothyroid disorders, asthma, anemia, hemostasis disorders, cardiovascular diseases including dyslipidemia, hypertension, and sleep apnea. After conducting the search using specific illnesses, general key words were used, such as home testing, consumer diagnostics, home test kits, home diagnostics, outpatient care, outpatient testing, home monitoring, ambulatory care, home care monitoring, and other variations of these terms. After inspection, the most relevant and pertinent information relating to the key word invariably appeared within (at most) the first five pages of the Google search. Thus, we relied on these relevant pages to gather home test information.

Other websites such as: healthhometest.com, homediagnostics.com, homehealthtesting.com and homeaccess.com provided a number of testing kits for many different diseases. Most of the sites provided a list of disorders, which the consumers could then search for a home test kit relating to their specific need. Other sites, such as healthtestingathome.com, not only provided a list of diseases to search, but also a list of manufacturers of each testing device to search through as well. All these sites were geared toward the consumer; they provided facts about the diseases and descriptive directions on how to use the home testing devices. We also searched internet consumer marketplaces such as Target.com, CVS.com, OscoDrug.com, Ebay.com, Amazon.com, americandiabeteswholesale.com, diabetesnet.com, and pricegrabber.com. Dozens of results for home testing devices that were sold at these stores appeared on each site.

All home testing devices found were recorded in a table. For each test we collected the following data: type of chronic diseases the device is used for, type of specimen, collection methodology, test results display method, methods of interpretation, and details of the manufacturer and/or distributor including name and website. (Table 1)

Following the original search conducted in December 2007, the collected list of home testing devices was crosschecked. This was performed by running a keyword (e.g., “blood glucose home test”) through the Google search engine, which then would return a large number of hits that included approximately a dozen to two dozen distributor websites. These distributor websites were then searched for additional home testing products. When a new home test was found that was not included in the original search, it was added to the list. After crosschecking the original searches, and adding the newly discovered home testing devices, each individual test was searched using the Google search engine to locate the manufacturer website and obtain pertinent information.

As the manufacturer and/or distributor websites varied in their description concerning the FDA regulatory status of the specific tests, we searched for the relevant information in the FDA website. Specifically, we searched the publicly accessible FDA 510(k) database for information regarding the FDA clearance status of the home test devices that were identified from our grey literature search using the following method: we searched the 510(k) database (accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm, accessed April 17^th^, 2008) by Product Code, Applicant Name (or the manufacturer), or Device Name. The Product Code identifies the generic category of a device. The following codes were searched:

- DXH: transmitters and receivers, electrocardiograph, telephone
- DPS: electrocardiograph
- CHH: enzymatic esterase--oxidase, cholesterol
- JKA: tubes, vials, systems, serum separators, blood collection
- DCK: c-reactive protein, antigen, antiserum, and control
- LCP: assay, glycosylated hemoglobin
- NBW: system, test, blood glucose, over the counter
- CGA: glucose oxidase, glucose
- JIR: indicator method, protein or albumin (urinary, non-quant.)
- KHG: whole blood hemoglobin determination
- GJS: test, time, prothrombin
- JLW: radioimmunoassay, thyroid-stimulating hormone
- DQA: oximeter
- BZH: meter, peak flow, spirometry

When the product name is not in the list of in vitro devices under each Product Code, the name of the product (or the brand name) was used as keyword for the search of the device name. If the device still could not be found, we searched for the name of the manufacturer and examined the relevant 510(k) documents. We also recorded the FDA regulatory status for the device into Table 1 when this information was available. When the information was not available, the status “no data” was entered.