# Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested a report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). The focus of this report was to propose a framework to evaluate home testing and to apply the framework to evaluate glycosylated hemoglobin (HbA1C) and cholesterol home tests in the management of chronic diseases. AHRQ assigned the report to the following Evidence-based Practice Center: Tufts Medical Center EPC (Contract No. HHSA 290 2007 100551).

The shift in the societal attitude that emphasizes an active participation of individuals in their health care,1 advances in technology, and the need to provide health care outside the traditional setting have led to the development, marketing, and popularity of home monitoring devices.2 At least 500 devices/tests have been approved or cleared by the FDA and marketed in the USA for home use3 and this number will rise as the demand for patient monitoring systems is expected to increase 5.4 percent annually to $9.1 billion in 2010.^4^

The need for ongoing and repeated test in the management of certain diseases is a major impetus for the development of home tests. Some home tests have been approved or cleared by the FDA for the diagnosis of acute or chronic illnesses and for disease management. Tests for pregnancy, Human Immunodeficiency Virus (HIV) and fecal occult blood are examples of the available tests that can be done in the home setting. Glucose and cholesterol/lipid tests and tests that assess drug levels or response to drug therapy such as prothrombin time for anticoagulation therapy are examples of the home tests available for the management of chronic diseases.

Potential tradeoffs for the increased privacy, speed and convenience of home tests (test kits) are erroneous results and interpretations, and faulty subsequent actions which may result in substandard care. However, home self testing could lead to closer monitoring of conditions and rapid implementation of changes that may translate into improved health outcomes, reduced number of patient encounters in the emergency department and hospital admissions.5

The purpose of this report is to adapt and apply the framework developed by Fryback and Thornbury6 (see below) to the assessment of glycosylated hemoglobin (HbA1c) and cholesterol home tests; these particular home tests are being reviewed at the behest of CMS. The Fryback and Thornbury approach has been used successfully in the EPC program to evaluate diagnostic technologies.7 This framework organizes published literature on diagnostic tests into six categories:

1. Technical feasibility: technical issues with the diagnostic test
2. Diagnostic accuracy: sensitivity and specificity
3. Diagnostic thinking: impact of test on physician subjective estimate of diagnostic probabilities pre- and post-test
4. Therapeutic efficacy: change in patient management due to test
5. Patient outcomes: proportion of patients improved with test compared to without test
6. Societal outcomes/cost effectiveness

This framework makes explicit the relationship between the diagnostic test and health outcomes. A test that is technically feasible and has high accuracy will provide the necessary information to help determine the best course of action and select the appropriate therapy and management; this will in turn affect patient outcomes and allow the assessment of societal benefits and weighing the corresponding cost effectiveness. CMS requested the evaluation of glycosylated hemoglobin (HbA1c) home testing in the management of diabetes and cholesterol home monitoring in the management of dyslipidemia using this framework. These two home tests are of interest because diabetes and dyslipidemia are prevalent and impose a substantial health burden to society.8 Their treatments are associated with substantial health benefits.9 HbA1c is used to confirm blood glucose test results and to assess the effectiveness of a treatment plan for patients with diabetes. It can also help in showing patients “how healthy choices can make a difference in diabetes control” (diabests.org/type-1-diabetes/a1c-test.jsp, accessed 9-26-2008). As high blood cholesterol level is a major risk factor for coronary heart disease and stroke, patients with high blood cholesterol concentration should be given appropriate therapy (lifestyle modifications with or without pharmacological regimens) and the blood cholesterol level followed to assess the effectiveness of the treatment program. Recent technology assessments have not considered either glycosylated hemoglobin or cholesterol measurements. Although glucose home testing has been extensively studied, the glycosylated hemoglobin home test deserves further evaluation; this will complement the 2005 technology assessment of point of care testing of HbA1c produced by the Duke EPC.10 In addition to the application of the framework to two home tests, CMS has also requested cataloguing the kinds of home tests currently available for the management of chronic diseases by examining the grey literature.

## Summary of tasks and key questions

1. The EPC will propose a framework vis-à-vis the Fryback and Thornbury model to perform future technology assessments of home testing.
2. Application of framework to HbA1c and cholesterol home tests
  a. Implementation feasibility (issues related to using the tests in a home setting)
    - What is the variability in results (or total random and systematic error) with a single testing device (precision or coefficient of variation) used in a home setting?
    - Do published studies of %HbA1c and cholesterol home tests assess variation of test results (e.g., due to collection by finger stick instead of venipuncture) in the home setting? Do any published studies follow accuracy or precision of home tests over an extended follow-up period of use in the home setting?
    - What training do patients need to use %HbA1c and cholesterol home tests correctly (i.e., to properly collect a sample; to perform the testing procedure; to recognize and interpret the result; to maintain or calibrate the home test)?
    - Are there patient characteristics associated with increased likelihood of correctly using home %HbA1c and cholesterol tests?
    - How do published studies define “patient adherence” with home testing (e.g., timing; accuracy; persistence)? What are the rates of patient adherence to home %HbA1c and cholesterol testing? What factors (e.g., patient-perceived pain of sample collection) or interventions (e.g., feedback from healthcare provider) have been found to be associated with improved or worsened patient adherence?
    - What if any requirements exist for maintenance or periodic re-calibration of home testing?
  b. Diagnostic accuracy of the tests used in a home setting
    - Have published studies assessed the test performance characteristics (e.g., accuracy, precision) of home %HbA1c and cholesterol tests? What “gold standard” methods of HbA1c or cholesterol measurement are used in assessment of home tests’ diagnostic accuracy?
  c. Impact of the test on diagnostic thinking and medical decision making
    - How are the results of the home testing for %HbA1c and cholesterol used in the studies? Are they part of a disease management plan?
    - Do home %HbA1c and cholesterol tests improve patients’ satisfaction with their care, compared to laboratory testing?
    - Does the use of home %HbA1c and cholesterol tests affect medical decision making and practice? If so, how? Are actions taken by the patient after consulting the healthcare provider, or autonomously?
    - Does the use of home %HbA1c and cholesterol tests obviate the use of laboratory tests for glycosylated hemoglobin and cholesterol?
  d. Impact of the test on patient outcomes
    - Does the use of home %HbA1c and cholesterol tests improve health outcomes? If so, which health outcomes have been improved, according to published studies?
    - What are the potential harms of home %HbA1c and cholesterol tests (e.g., false positive and false negative results, more workups, self changes in drug schedules that led to adverse events, etc)?
3. Horizon Scan:
  a. What home tests are currently available for management of chronic disease in patients at least 65 years old?
  b. What types of specimens are used in home tests for chronic disease management?
  c. Summarize publicly available information on tests that are currently under FDA pre-approval review.