# Discussion

We have suggested a theoretical framework to evaluate a home test. Adoption of such a framework in future evaluation is likely to provide helpful information. In our view, an ideal home test would have the following properties: 1) useful in chronic disease management and improving health outcomes, 2) simple and easy to use with minimal operator dependency, 3) provides unambiguous result, 4) has a built-in control testing system, and 5) cost-effective. Because of the paucity of data concerning the evaluation of testing for hemoglobin A1c or cholesterol in a home setting, we are not able to provide definitive answers posed by the key questions. The AHRQ technology assessment on point of care testing of hemoglobin A1c in 2005^10^ similarly identified only one study that took place in a home setting.38 There are many studies on point-of-care testing. But data gathered from evaluation of a test in a point of care setting could and should not be generalized to a home setting because of differences in operator expertise, training, and other factors. Evaluation of a potential home test using the Fryback and Thornbury model will allow one to properly comprehend the utility of such a test. Also, one needs to bear in mind the difference between an efficacy and an effectiveness trial. Efficacy studies tend to take place in controlled settings for relatively short periods. For instance, home blood pressure monitoring has only been tested in clinical efficacy trials, but not in the effectiveness settings. “These devices have not been regularly incorporated into clinical care to assist primary care providers in treating their patients”.39 Real world experiences will also be needed in assessing a test’s true effectiveness.

Our horizon scan showed that many of the tests marketed for chronic disease management have been either approved or cleared by the FDA. Some tests’ regulatory status was unclear; reasons are not immediately apparent. We speculate that some of the manufacturers’ and distributors’ websites might have marketed the same test under slightly different names and made verification via cross-matching between different databases not possible.

## Future studies

A randomized controlled study in a real world setting would be ideal in evaluating the efficacy of a specific home test in improving health outcomes. The study could compare home test with no test or with other forms of testing (e.g., in vitro diagnostic testing in physician’s office with immediate availability of result, conventional laboratory testing with result available only sometime after the health care visit). It must be cautioned that even with well-established randomization technique, it will not be easy to control for the many variables that affect the course of a chronic disease and its attendant health outcomes. It is also not easy to determine what health outcomes will be of interest. Post-marketing observational data will help assess the effectiveness of such a testing regimen. Such data should report any improved health outcomes as well as harms (e.g., consequences of false positive and false negative results like repeated needs of confirmatory testing, unnecessary anxiety, and excessive dosages of medications). A testing device with a built in memory chip could be programmed to record results as well as adherence to testing routine. Such device could also be designed to keep track of disease flare-ups. This will help promote further understanding of a particular relationship between test results and the chronic disease of interest. Large databases that collect health outcome and healthcare utilization pattern could also be examined to see if there is any relationship between the introduction of a specific home test and those data. As the Internet continues to expand, one will also need to assess the impact of telemedicine and related emerging technologies (e.g., home blood glucose result made available to the provider immediately over the Internet).