# Reference List

1 Neuberger J. Do we need a new word for patients? Lets do away with "patients". BMJ. June. 26. 1999;318(7200):1756-1757. [pmid: 10381717].
2 Lehmann C. Management of point-of-care testing in home health care. Clin Leadersh Manag Rev. January. 2002;16(1):27-31. [pmid: 11828784].
3 CDRH. FDA. Center for devices and radiological health. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfCLIA/clia.cfm. 2007. Accessed1907. Available at: URL: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfCLIA/clia.cfm.
4 Kyriakos T. Self-care, innovation boost today's home health offering - brief article - statistical data included. http://findarticles.com/p/articles/mi_m3374/is_4_22/ai_61492765. 2000. Available at: URL: http://findarticles.com/p/articles/mi_m3374/is_4_22/ai_61492765.
5 Lehmann CA. The future of home testing--implications for traditional laboratories. Clin Chim Acta. September. 2002;323(1–2):31-36. [pmid: 12135805].
6 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. April. 1991;11(2):88-94. [pmid: 1907710].
7 Tatsioni A, Zarin DA, Aronson N, et al. Challenges in systematic reviews of diagnostic technologies. Ann Intern Med. June. 21. 2005;142(12 Pt 2):1048-1055. [pmid: 15968029].
8 Khot UN, Khot MB, Bajzer CT, et al. Prevalence of conventional risk factors in patients with coronary heart disease. JAMA. August. 20. 2003;290(7):898-904. [pmid: 12928466].
9 Grover SA, Paquet S, Levinton C, Coupal L, Zowall H. Estimating the benefits of modifying risk factors of cardiovascular disease: a comparison of primary vs secondary prevention. Arch Intern Med. March. 23. 1998;158(6):655-662. [pmid: 9521231].
10 Duke Evidence-based Practice Center. Point of Care Testing of Hemoglobin A1c. http://www.cms.hhs.gov/determinationprocess/downloads/id35TA.pdf. 2005.
11 Vincze G, Parthan A. The value of home monitoring kits in diabetes, hypertension, asthma, and oral anticoagulation therapy. Journal of Pharmacy Practice. 2004;17(3):182-196.
12 Consensus statement on self-monitoring of blood glucose. Diabetes Care. January. 1987;10(1):95-99. [pmid: 3552518].
13 Greenwald JL, Burstein GR, Pincus J, Branson B. A rapid review of rapid HIV antibody tests. Current Infectious Disease Reports. March. 2006;8(2):125-131. [pmid: 16524549].
14 Samsa GP, Matchar DB. Relationship between test frequency and outcomes of anticoagulation: a literature review and commentary with implications for the design of randomized trials of patient self-management. [Review] [37 refs]. Journal of Thrombosis & Thrombolysis. April. 2000;9(3):283-292. [pmid: 10728029].
15 Tran N, Kost, Gerald J. Guidelines for Home Testing in Primary Care: Education, Integration, Information, Limitations, and Indications. Point of Care: The Journal of Near-Patient Testing and Technology. 2006;5(4):145-154. Ref Type: Generic.
16 Scolaro KL, Stamm PL, Lloyd KB. Devices for ambulatory and home monitoring of blood pressure, lipids, coagulation, and weight management, part 2. Am J Health Syst Pharm. September. 15. 2005;62(18):1894-1903. [pmid: 16141109].
17 Datta AK, Selman TJ, Kwok T, Tang T, Khan KS. Quality of information accompanying on-line marketing of home diagnostic tests. Journal of the Royal Society of Medicine. January. 2008;101(1):34-38. [pmid: 18263912].
18 Walford S, Alberti KG. Biochemical self-monitoring: promise, practice and problems. Contemp Issues Clin Biochem. 1985;2:200-213. [pmid: 3842345].
19 Sustained effect of intensive treatment of type 1 diabetes mellitus on development and progression of diabetic nephropathy: the Epidemiology of Diabetes Interventions and Complications (EDIC) study. JAMA. October. 22. 2003;290(16):2159-2167. [pmid: 14570951].
20 Gibson PG, Coughlan J, Wilson AJ, et al. Self-management education and regular practitioner review for adults with asthma. Cochrane Database Syst Rev. 2000;(2):CD001117. [pmid: 10796600].
21 Cromheecke ME, Levi M, Colly LP, et al. Oral anticoagulation self-management and management by a specialist anticoagulation clinic: a randomised cross-over comparison. Lancet. July. 8. 2000;356(9224):97-102. [pmid: 10963245].
22 Miller CD, Barnes CS, Phillips LS, et al. Rapid A1c availability improves clinical decision-making in an urban primary care clinic. Diabetes Care. April. 2003;26(4):1158-1163. [pmid: 12663590].
23 Thaler LM, Ziemer DC, Gallina DL, et al. Diabetes in urban African-Americans. XVII. Availability of rapid HbA1c measurements enhances clinical decision-making. Diabetes Care. September. 1999;22(9):1415-1421. [pmid: 10480502].
24 Beer SF, Lawson C, Watkins PJ. Neurosis induced by home monitoring of blood glucose concentrations. BMJ. February. 11. 1989;298(6670):6362.
25 Tang Z, Lee JH, Louie RF, Kost GJ. Effects of different hematocrit levels on glucose measurements with handheld meters for point-of-care testing. Arch Pathol Lab Med. August. 2000;124(8):1135-1140. [pmid: 10923072].
26 Rector TS, Venus PJ, Thayer SR. Use of home hemoglobin A1c test kits to monitor the effectiveness of diabetes care. Joint Commission Journal on Quality Improvement. May. 2001;27(5):265-277. [pmid: 11367774].
27 Gutman S, Richter K, Alpert S. Update on FDA regulation of in vitro diagnostic devices. JAMA. July. 8. 1998;280(2):190-192. [pmid: 9669798].
28 Food and Drug Administration. Guidance for 510(k) on Cholesterol Tests for Clinical Laboratory, Physicians' Office Laboratory and Home Use. Rockville, Maryland. 1995.
29 Abel LL, Levy BB, Brodie BB, Kendall FE. A simplified method for the estimation of total cholesterol in serum and demonstration of its specificity. J Biol Chem. March. 1952;195(1):357-366. [pmid: 14938387].
30 Delamater AM, Bubb J, Davis SG, et al. Randomized prospective study of self-management training with newly diagnosed diabetic children. Diabetes Care. May. 1990;13(5):492-498. [pmid: 2351027].
31 Home testing of cholesterol. Medical Letter on Drugs & Therapeutics. September. 30. 1994;36(932):85-86. [pmid: 8084304].
32 Noble D. Home test for cholesterol. Look, ma, no instrument. Analytical Chemistry. December. 1. 1993;65(23):1037-1041. [pmid: 8297022].
33 Ross J. Home test measures total cholesterol. Nurse Practitioner. July. 2003;28(7 Pt 1):52-53. [pmid: 14533648].
34 Klonoff DC, Bergenstal RM, Cole TG, et al. Clinical Evaluation of a Rapid A1C Test (A1CNow) for Home Use. Point of Care: The Journal of Near-Patient Testing and Technology. September. 2006;5(3):116-120.
35 Kordella T. Home A1C test on the way. Diabetes Forecast. June. 2002;55(6):47-48. [pmid: 14964168].
36 Ruder K. At-home A1C device flawed. Diabetes Forecast. May. 2007;60(6):40. [pmid: 17566224].
37 Parkes J, Ray R, Kerestan S, Davis H, Ginsberg B. Prospective evaluation of accuracy, precision, and reproducibility of an at-home hemoglobin A1c sampling kit.[see comment]. Diabetes Technology & Therapeutics. 1999;1(4):411-419. [pmid: 11474825].
38 Holman RR, Jelfs R, Causier PM, Moore JC, Turner RC. Glycosylated haemoglobin measurement on blood samples taken by patients: an additional aid to assessing diabetic control. Diabet Med. January. 1987;4(1):71-73. [pmid: 2951227].
39 Bosworth HB, Olsen MK, Dudley T, et al. The Take Control of Your Blood pressure (TCYB) study: study design and methodology. Contemp Clin Trials. January. 2007;28(1):33-47. [pmid: 16996808].