# Workshop Proceedings

This document summarizes the views and issues addressed by invited speakers and discussants at the Surgeon General’s Workshop on Healthy Indoor Environment. The views expressed in these Proceedings reflect the opinions of the individual participants at the Workshop and do not necessarily reflect the official position of the Office of the Surgeon General, the Department of Health and Human Services, or other federal entities.

Welcome

Charge and Goals

What is the scientific evidence for health problems associated with the indoor environment? Day 1: First Morning Session

What are the challenges to bringing about health-promoting changes in indoor environments? Day 1: Second Morning Session

What are the research needs related to public health and the indoor environment? Day 1: Afternoon Session

The Importance of Collaborative Efforts between the Building, Medical and Public Health Communities to Achieve Health-Promoting Changes in Indoor Environments

Review of Federal Research and Development and Outreach Activities: A Federal Agency Panel: Day 2: First Morning Session

Review of Federal Research and Development and Outreach Activities: Questions for the Federal Agency Panel: Day 2: Second Morning Session

Vision for the Future: Day 2: Afternoon Session

Closing and Action Steps