# Welcome

RADM Robert C. Williams, P.E., DEE

U.S. Public Health Service Chief Engineer

The Surgeon General’s Workshop on Healthy Indoor Environment (HIE) was called to order on January 12, 2005 by Rear Admiral (RADM) Robert C. Williams. RADM Williams welcomed participants and outlined the first day’s sessions, which would review scientific evidence showing a need for HIE, present information about HIE factors and their impact on health, and identify gaps in information that need to be assigned priorities so that action can be taken to promote pubic health and well-being. He then introduced the Surgeon General, Vice Admiral (VADM) Richard H. Carmona, who set the charge and goals for the workshop.