# Acknowledgments

The Surgeon General expresses his sincere appreciation to all who contributed time, experience, and knowledge to support the development of the Surgeon General’s Workshop on Healthy Indoor Environment and this report. The Surgeon General would especially like to acknowledge the following:

## THE ENGINEER PROFESSIONAL ADVISORY COMMITTEE

The Engineer Professional Advisory Committee (EPAC) provides advice and consultation to the U.S. Public Health Service (PHS) Chief Engineer, who in turn reports to the Surgeon General on matters relating to professional engineering issues. As part of its efforts to advance public health engineering and improve the health status of Americans, the various members of the Building and Design Subcommittee, EPAC, have worked diligently for several years to foster the development of this workshop. Their dedication to this initiative truly reflects the PHS Engineering Category motto of Machinatores Vitae (Engineering for Life).

## THE PUBLIC

Approximately 300 people attended the Surgeon General’s Workshop on Healthy Indoor Environment. The participants provided valuable insight concerning the indoor environment, which help guide the development of this report.

## GOVERNMENT AGENCIES

The Surgeon General’s Workshop on Healthy Indoor Environment was sponsored by the following government agencies in the Department of Health and Human Services:

- Agency for Toxic Substances and Disease Registry
- Centers for Disease Control and Prevention
- National Institutes of Health

In addition, the following federal agency and federal council sponsored the workshop:

- U.S. Environmental Protection Agency
- National Science and Technology Council

## PLANNING AND COORDINATION GROUP

The Surgeon General would especially like to recognize the following individuals for their assistance in organizing the workshop and preparing this report.

Workshop Coordinator

CAPT Sven E. Rodenbeck, Sc.D., P.E., BCEE

Group Members

CAPT (ret) Bill Brodt

Clive Brown, M.B.B.S., M.Sc., M.P.H.

CAPT Susan Conrath, Ph.D., M.P.H.

Jean Cox-Ganser, Ph.D.

Allen Dearry, Ph.D.

CDR Margaret M. Kitt, M.D., M.P.H.

Brian Kong, P.E.

CAPT Allan Noonan, M.D., M.P.H.

CAPT Stephen Redd, M.D.

Jim Rifenburg

RADM Robert C. Williams, P.E., BCEE