# Participant List

- Darryl L. Alexander
- Director
- American Federation of Teachers
- Health and Safety
- 555 New Jersey Avenue, NW
- Washington, DC 20001
- Phone: 202-393-5674
- E-mail: dalexand@aft.org

- Bridget K. Ambrose, M.P.H.
- Emerging Leaders Fellow
- Centers for Disease Control and Prevention
- 906 Briarcliff Road #2
- Atlanta, GA 30306
- Phone: 404-639-5125
- E-mail: cvz3@cdc.gov

- Jeremy S. Ames
- Environmental Protection Specialist
- U.S. Environmental Protection Agency
- Indoor Environment
- 1200 Pennsylvania Avenue, NW
- Washington, DC 20460
- Phone: 202-343-9615
- Fax: 202-343-2394
- E-mail: ames.jeremy@epa.gov

- Marjory E. Anderson, A.S.P.
- Safety Engineer
- Architect of the Capitol
- Safety and Occupational Health Branch
- 2nd & D Streets, SW
- Ford House Office Building
- Washington, DC 20515
- Phone: 202-226-3416
- Fax: 202-226-9915
- E-mail: manderso@aoc.gov

- Norman T. Anderson, M.S.P.H.
- Research Coordinator
- American Lung Association of Maine
- 122 State Street
- Augusta, ME 04330
- Phone: 207-622-6394
- E-mail: nanderson@mainelung.org

- Stephen P. Ashkin
- President
- The Ashkin Group
- 3644 Tamarron Drive
- Bloomington, IN 47408
- Phone: 812-332-7950
- Fax: 812-332-7965
- E-mail: SteveAshkin@AshkinGroup.com

- Peter J. Ashley, Dr.P.H.
- Environmental Scientist
- U.S. Department of Housing and Urban Development
- Office of Healthy Homes
- 451 7th Street, SW, Room P3206
- Washington, DC 20410
- Phone: 202-755-1785 x115
- Fax: 202-755-1000
- E-mail: peter_j._ashley@hud.gov

- Michael B. Atkinson
- Program Expert/Architect
- U.S. General Services Administration
- Office of Governmentwide Policy
- Innovative Workplaces Division (MPW)
- 1800 F Street, NW, Suite 6213, MPW
- Washington, DC 20405
- Phone: 202-439-1251
- Fax: 202-273-4670
- E-mail: michael.atkinson@gsa.gov

- Laura E. Bailey
- Senior Environmental Scientist
- U.S. Environmental Protection Agency
- Antimicrobials Division
- 1200 Pennsylvania Avenue, NW, MS-7510C
- Washington, DC 20460
- Phone: 703-308-6212
- Fax: 703-308-6467
- E-mail: bailey.laura@epa.gov

- Marion Balsam, M.D., F.A.A.P.
- Research Partnerships Program Director
- National Institutes of Health
- National Institute of Child Health and Human Development
- The National Children’s Study
- 6100 Executive Boulevard, Suite 5C01
- Bethesda, MD 20892-7510
- Phone: 301-435-7679
- Fax: 301-480-1222
- E-mail: balsamm@nih.gov

- Jim Jian Bao, Ph.D.
- Microbiology Laboratory Director
- EMSL Analytical, Inc.
- 10768 Baltimore Avenue
- Beltsville, MD 20705
- Phone: 301-937-5700
- Fax: 301-937-5701
- E-mail: jbao@emsl.com

- Claire L. Barnett, M.B.A.
- Executive Director
- Healthy Schools Network, Inc.
- 773 Madison Avenue, 1st floor
- Albany, NY 12208
- Phone: 518-462-0632
- Fax: 518-462-0433
- E-mail: cbarnett@healthyschools.org

- LT Jason E. Barr, C.I.H.
- National Institutes of Health
- Building 13, Room 3K04
- 13 South Drive, MSC 5760
- Bethesda, MD 20892-5760
- Phone: 301-451-5818
- Fax: 301-402-0313
- E-mail: jbarr@nih.gov

- CAPT Richard F. Barror, Ph.D., M.P.H.
- Senior Engineer
- U.S. Food and Drug Administration
- Office of the Commissioner, P.O. Box 1273
- Rockville, MD 20849
- Phone: 301-827-8799
- Fax: 301-827-0017
- E-mail: richard.barror@fda.gov

- Carol M. Bass, Ph.D.
- Environmental Engineer
- 5736 Buckhaven Court
- Alexandria, VA 22315
- Phone: 703-924-0681
- Fax: 703-924-0690
- E-mail: bass.carol@epa.gov

- Charlene W. Bayer, Ph.D.
- Principal Research Scientist/Branch Head
- Georgia Tech Research Institute
- EOEML/SHETD
- 925 Dalney Street, MC 0820
- Atlanta, GA 30332-0820
- Phone: 404-894-5361
- Fax: 404-894-3946
- E-mail: charlene.bayer@gtri.gatech.edu

- Edward S. Belcastro, P.E.
- Mechanical Engineer
- National Institutes of Health
- Office of Research Facilities
- Division of Property Management
- Facilities Technical Support Team
- 10 Center Drive, MSC 1901, Room 12B19
- Bethesda, MD 20892-1901
- Phone: 301-496-0819
- Fax: 301-402-0225
- E-mail: belcaste@mail.nih.gov

- LCDR Lisa G. Benaise, M.D., M.P.H.
- Epidemic Intelligence Service Officer
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- Division of Respiratory Disease Studies
- 1095 Willowdale Road, Suite H-2800
- Morgantown, WV 26505
- Phone: 304-285-6139
- Fax: 304-285-5820
- E-mail: aju6@cdc.gov

- Sheri Bernstein
- Branch Chief, Policy
- National Institutes of Health
- Office of Research Facilities
- Division of Policy and Program Assessment
- Building 13, Room 201
- Bethesda, MD 20892
- Phone: 301-594-9506
- E-mail: sb387u@nih.gov

- Tobie Bernstein, J.D.
- Senior Attorney
- Environmental Law Institute
- 2000 L Street, NW, Suite 620
- Washington, DC 20036
- Phone: 202-939-3869
- Fax: 202-939-3868
- E-mail: bernstein@eli.org

- Kristen A. Bertram
- Community Services Associate
- National Association of Counties
- Community Services Association
- 440 First Street, NW
- Washington, DC 20001
- Phone: 202-942-4292
- Fax: 202-661-8871
- E-mail: kbertram@NACO.org

- James R. Biasco, P.E.
- Director
- Indian Health Service
- Division of Facilities Operations
- 12300 Twinbrook Parkway, 600B
- Rockville, MD 20852
- Phone: 301-443-8027
- E-mail: james.biasco@ihs.hhs.gov

- Irwin H. Billick, Ph.D.
- President
- WEC Consulting
- 10408 Crossing Creek Road
- Potomac, MD 20854
- Phone: 301-299-5302
- E-mail: wecltd@comcast.net

- Randey A. Bloom, C.P.M.M.
- Postal Maintenance Specialist
- U.S. Postal Service
- Engineering
- 8403 Lee Highway
- Dewey Building
- Merrifield, VA 22082-8101
- Phone: 703-280-7918
- Fax: 703-280-8415
- E-mail: randey.a.bloom@usps.gov

- Fred Blosser
- Public Affairs Officer
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- 200 Independence Ave., SW
- Washington, DC 20201
- Phone: 202-260-8519
- Fax: 202-260-1898
- E-mail: fbb0@cdc.gov

- Catherine C. Bobenhausen, C.I.H., L.E.E.D.A.P., C.S.P.
- 54 Ashley Road
- Hastings-on-Hudson, NY 10706
- Phone: 914-584-8094
- Fax: 914-478-1676
- E-mail: cbobenhausen@sdcollab.com

- Gerald G Bowen
- Occupational Safety & Health Specialist
- U.S. Department of Agriculture
- Office of Operations
- 1400 Independence Avenue, SW
- Mail Stop 9877
- Washington, DC 20817
- Phone: 202-720-0426
- Fax: 202-720-9976
- E-mail: Becky.Garbarino@usda.gov

- Jerry Bowen
- Safety and Environmental Specialist
- U.S. Department of Agriculture
- Protective Operations Division
- Safety and Environmental Branch
- Office of Operations
- 1400 Independence Avenue, SW
- Washington, DC 20250-9377
- Phone: 202-720-0426
- Fax: 202-720-9976
- E-mail: geraldg.bowen@usda.gov

- Gina L. Bowler
- Special Assistant
- U.S. Environmental Protection Agency
- Indoor Environment
- 1200 Pennsylvania Avenue, NW
- Mail Code 6609J
- Washington, DC 20460
- Phone: 202-343-9206
- Fax: 202-343-2394
- E-mail: bowler.gina@epa.gov

- Percival S. Brereton, M.S.
- Industrial Hygienist
- National Institutes of Health
- Office of Research Services
- Division of Occupational Health and Safety
- Building 13, Room 3K04
- Bethesda, MD 20892-5760
- Phone: 301-451-5801
- Fax: 301-402-0313
- E-mail: Breretop@ORS.od.nih.gov

- Catherine A. Broad
- Architect
- General Services Administration
- Public Buildings Service
- 10024 Pratt Place
- Silver Spring, MD 20910
- Phone: 202-439-7250
- E-mail: catherine.broad@gsa.gov

- Ann Brockhaus, M.P.H.
- Occupational Health Consultant
- ORC Worldwide
- 1800 K Street, NW
- Washington, DC 20006
- Phone: 202-293-2980
- Fax: 202-293-2915
- E-mail: brockhaus@orc-dc.com

- William Brodt, M.S.E.
- Experimental Facilities Engineer
- National Aeronautics and Space Administration
- Facilities Engineering and Real Property Division
- 300 E Street, SW
- Washington, DC 20546
- Phone: 202-358-1117
- Fax: 202-358-3848
- E-mail: wbrodt@nasa.gov

- Barbara A. Brooks, M.P.H., R.N., C.I.A.Q.P., C.O.H.N.-S.
- Industrial Hygienist
- National Security Agency
- Occupational Health & Safety
- 9800 Savage Road, Suite 6404
- Fort Meade, MD 20755-6000
- Phone: 410-854-7121
- Fax: 301-688-2423
- E-mail: babrook@nsa.gov

- Cherie M. Brown, M.P.A.
- Analyst
- U.S. General Services Administration
- Office of Governmentwide Policy
- 1800 F Street, NW, Suite 6213
- Washington, DC 20405
- Phone: 202-208-6771
- Fax: 202-273-4670
- E-mail: cherie.mcclambrown@gsa.gov

- Clive M. Brown, M.B.B.S., M.Sc., M.P.H.
- Medical Epidemiologist
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- Division of Environmental Hazards and Health Effects
- Air Pollution and Respiratory Health Branch
- 1600 Clifton Road
- MS-E17
- Atlanta, GA 30333
- Phone: 404-498-1000
- E-mail: cmb8@cdc.gov

- Sharunda Buchanan, Ph.D.
- Branch Chief
- Centers for Disease Control & Prevention
- National Center for Environmental Health
- Division of Emergency and Environmental Health Services
- 4770 Buford Highway, NE
- Mailstop F-28
- Atlanta, GA 30341
- Phone: 770-488-7362
- E-mail: SBuchanan@cdc.gov

- Nathaniel Burden
- Fidelity Inspection & Consulting Service
- 626 Jacksonville Road, Suite 200
- Warminster, PA 18974
- Phone: 215-953-9200
- E-mail: nburden@ficservices.com

- David A. Butler, Ph.D.
- Senior Program Officer
- National Academy of Sciences
- Institute of Medicine
- 500 Fifth Street, NW, Keck 872
- Washington, DC 20001
- Phone: 202-334-2000
- E-mail: mold@nas.edu

- Richard Callan
- ASPH-EPA Fellow
- U.S. Environmental Protection Agency
- ORD/NCER, Mail Code 8723F
- 1025 F Street NW, Room 3125G
- Washington, DC 20004
- Phone: 202-343-9637
- E-mail: callan.richard@epa.gov

- VADM Richard H. Carmona, M.D., M.P.H., F.A.C.S.
- United States Surgeon General
- Office of the Surgeon General
- U.S. Public Health Service
- 5600 Fishers Lane
- Parklawn Building, Room 18–67
- Rockville, MD 20857
- Phone: 301-443-4000
- E-mail: rcarmona@osophs.dhhs.gov

- Joseph P. Carrier
- Industrial Hygienist
- Johns Hopkins University
- Applied Physics Laboratory
- Environmental Health and Safety
- 11100 Johns Hopkins Road
- Laurel, MD 20723-6099
- Phone: 443-778-4190
- Fax: 443-778-6250
- E-mail: joseph.carrier@jhuapl.edu

- Jennifer L. Carter
- Art Consultant
- Maple Avenue, Takoma Park, MD 20912
- Phone: 301-891-3214
- Fax: 301-270-1441
- E-mail: sanghacafe@starpower.net

- Daniel W. Cautley, P.E.
- Cautley Engineering
- 3611 39th Street, NW, Apartment C327
- Washington, DC 20016
- Phone: 202-244-2488
- E-mail: dwcautley@mindspring.com

- John C. Chah, Ph.D.
- President
- Global BioTech, LLP
- 1984 Lancashire Drive
- Potomac, MD 20854
- Phone: 301-424-8720
- Fax: 301-424-0300
- E-mail: sbrjchah@fastmail.fm

- Jae Chang
- Professor
- University of Kansas
- Architecture
- 1465 Jayhawk Boulevard
- 416 Marvin Hall
- Lawrence, KS 66045
- Phone: 785-864-1446
- E-mail: jdchang@ku.edu

- Helen T. Chatham, M.S.N.
- Nurse Practitioner
- U.S. Department of Defense
- Occupational Health and Environmental Safety
- 8621 Concord Drive
- Jessup, MD 20794
- Phone: 301-617-2631
- E-mail: irishpride0703@comcast.net

- Harry F. Chisholm
- IAQ Manager
- National Security Agency
- Facilities
- 9800 Savage Road
- Fort Meade, MD 20755-6000
- Phone: 301-688-7824
- Fax: 301-688-2423
- E-mail: hfchish@nsa.gov

- Kevin Choe, M.P.H., Ph.D.
- IAQ Professional
- Q Air Systems, Inc.
- 52 Edgefield Drive
- Morris Plains, NJ 07950
- Phone: 973-656-9833
- E-mail: choek@optonline.net

- Mary E. Clancy Czarnecki, R.N., C.I.E., C.M.R.
- Director of Environmental Health
- EDDI
- Environmental Assessment & Analysis
- 168 Magnolia Road
- Sterling, VA 20164
- Phone: 703-450-9460, 703-431-3014
- Fax: 703-406-8807
- E-mail: maryclancy@earthlink.net

- Noreen M. Clark, Ph.D.
- Dean
- University of Michigan School of Public Health
- Marshall H. Becker Professor of Public Health
- 109 South Observatory Street
- Ann Arbor, MI 48109-2029
- Phone: 734-763-5454
- Fax: 734-763-5455
- E-mail: nmclark@umich.edu

- Anthony Clifford
- Chief Engineer
- National Institutes of Health
- Office of Research Facilities
- Office of the Director
- NIH, Building 13, Suite 201
- MSC 5759
- Bethesda, MD 20892-0158
- Phone: 301-594-0999
- Fax: 301-496-7172
- E-mail: Cliffort@ors.od.nih.gov

- Katy Coleman
- Associate Editor
- Environmental Education Foundation
- CM/Cleaning & Maintenance Management Magazine
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Sara Coley
- Project Manager
- E. Roberts Alley & Associates, Inc.
- 1931 Central Parkway SW
- Decatur, AL 35601
- Phone: 256-351-0121
- Fax: 256-351-0151
- E-mail: sarac@eralley.com

- David Anthony Collins
- Research Associate
- Johns Hopkins University
- Clinical Immunology
- 2801 Bayonne Avenue
- Baltimore, MD 21214
- Phone: 410-550-2560
- E-mail: dcollin8@jhmi.edu

- Pedro I. Colon
- Architect, Project Executive
- Smithsonian Institution
- Office of Planning & Project Management
- 750 9th Street NW, Suite 5200
- Washington, DC 20560-0908
- Phone: 202-275-0236
- Fax: 202-275-0889
- E-mail: colonp@si.edu

- CAPT Susan M. Conrath, Ph.D., M.P.H.
- U.S. Environmental Protection Agency
- Indoor Environment
- 1200 Pennsylvania Avenue, NW
- Washington, DC 20460
- Phone: 202-343-9389
- Fax: 202-343-2393
- E-mail: conrath.susan@epa.gov

- Leslie R. Cook
- U.S. Environmental Protection Agency
- Pollution Prevention
- USEPA Headquarters, MC 7409-M
- EPA East
- 1200 Pennsylvania Avenue, NW
- Washington, DC 20460
- Phone: 202-564-8838
- Fax: 202-564-8899
- E-mail: cook.leslie@epa.gov

- Elizabeth Cotsworth
- Office Director
- U.S. Environmental Protection Agency
- Radiation and Indoor Air
- 1200 Pennsylvania Avenue, NW
- Mail Code 6609J
- Washington, DC 20460
- Phone: 202-343-9320
- Fax: 202-343-2394
- E-mail: cotsworth.elizabeth@epa.gov

- Michele Courville
- Program Manager
- Montgomery County Department of Environmental Protection
- Indoor Environments
- 255 Rockville Pike, Suite 120
- Rockville, MD 20850
- Phone: 240-777-7757
- Fax: 240-777-7752
- E-mail: michele.courville@montgomerycountymd.gov

- Jean Cox-Ganser, Ph.D.
- Supervisory Research Epidemiologist
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- Division of Respiratory Disease Studies
- Field Studies Branch
- 1095 Willowdale Road
- MS 2800
- Morgantown, WV 26505
- Phone: 304-285-5751
- Fax: 304-285-5820
- E-mail: jjc8@cdc.gov

- LCDR David B. Cramer, R.S., M.P.H.
- Institutional Environmental Health Resident
- Indian Health Service
- Office of Environmental Health
- 12300 Twinbrook Parkway, Suite 610
- Rockville, MD 20852
- Phone: 301-443-1054
- Fax: 301-443-7538
- E-mail: david.cramer@ihs.gov

- Neil C. Davis, C.I.H., M.S., M.P.H.
- Senior Industrial Hygienist
- U.S. Department of Labor
- Occupational Safety and Health Administration
- Directorate of Standards and Guidance
- 1 Kentbury Way
- Bethesda, MD 20814
- Phone: 202-693-2281
- E-mail: Davis.Neil@DOL.gov

- Roy Deitchman
- VP - Environment Health & Safety
- Amtrak
- 60 Massachusetts Avenue, NE
- Washington, DC 20002
- Phone: 202-906-3278
- Fax: 202-906-3500
- E-mail: deitchr@amtrak.com

- Richard Denbow
- Metropolitan Washington Council of Governments
- 206 North Center Street
- Vienna, VA 22180
- Phone: 703-319-9300
- E-mail: rdenbow@earthlink.net

- Jim E. Dennison, Ph.D., C.I.H.
- Colorado State University
- ERHS
- CETT
- 1690 Campus Delivery
- Fort Collins, CO 80523
- Phone: 970-491-8867
- Fax: 970-491-8304
- E-mail: dennison@colostate.edu

- Jen Desimone
- Ozone Action Days Coordinator/Environmental Planner
- Metropolitan Washington Council of Governments
- Department of Environmental Programs
- 777 North Capitol Street, NE, Suite 300
- Washington, DC 20002-4239
- Phone: 202-962-3360
- Fax: 202-962-3203
- E-mail: jdesimone@mwcog.org

- CDR Danielle Devoney, Ph.D.
- U.S. Environmental Protection Agency
- Office of Research and Development
- 1200 Pennsylvania Avenue, NE, 8601D
- Washington, DC 20460
- Phone: 202-564-3352
- E-mail: devoney.danielle@epa.gov

- Thomas S. Dietsche
- Program Manager
- U.S. Green Building Council
- LEED Department
- 1015 18th Street NW, Suite 508
- Washington, DC 20036
- Phone: 202-828-1136
- E-mail: tdietsche@usgbc.org

- John DiFazio, J.D., M.P.A.
- Assistant General Counsel
- Consumer Specialty Products Association
- 900 17th Street NW, #300
- Washington, DC 20006
- Phone: 202-872-8110
- Fax: 202-872-8114
- E-mail: jdifazio@cspa.org

- Jerome P. Dion
- Supervisor, Research
- U.S. Department of Energy
- Building Technologies Program
- Energy Efficiency and Renewable Energy
- 1000 Independence Avenue, SW
- Washington, DC 20585-0121
- Phone: 202-586-9470
- Fax: 202-586-4617
- E-mail: jerry.dion@ee.doe.gov

- Eleanor Dixon-Terry, M.P.H., C.H.E.S.
- Director, Professional Development
- Society for Public Health Education
- 750 First Street, NE, Suite 910
- Washington, DC 20002
- Phone: 202-408-9804
- Fax: 202-408-9815
- E-mail: edixon-terry@sophe.org

- Jason Dobranic, Ph.D., R.I.A.Q.M.
- Environmental Education Foundation
- EMSL Analytical
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Marc Donate, Assoc. A.I.A., A.S.A.I.
- Bernardon Haber Holloway Architects, PC
- 425 McFarlan Road, Suite 200
- Kennett Square, PA 19348
- Phone: 610-444-2900
- E-mail: MDonate@bernardon.com

- Ken F. Doolan, C.I.H.
- U.S. Department of State
- M/OBO/OM/SHEM
- Washington, DC 20522-0611
- Phone: 703-812-2315
- Fax: 703-516-1958
- E-mail: doolankf@state.gov

- Heidi Dudik
- National Heart, Lung, and Blood Institute
- 9000 Rockville Pike
- Bethesda, MD 20892
- Phone: 301-451-8264
- E-mail: dudikh@nhlbi.nih.gov

- Kevin H. Dunn, C.I.H.
- Industrial Hygienist/Engineer
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- Division of Environmental Hazards and Health Effects
- 1600 Clifton Road, NE
- MS E-17
- Atlanta, GA 30333
- Phone: 404-498-2153
- Fax: 404-498-1088
- E-mail: kdunn@cdc.gov

- CDR Scott Earnest, Ph.D., P.E.
- Acting Branch Chief
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- Division of Applied Research and Technology
- 4676 Columbia Parkway
- Cincinnati, OH 45241
- Phone: 513-841-4539
- Fax: 513-841-4506
- E-mail: GEarnest@cdc.gov

- John P. Eberhard, F.A.I.A.
- Executive Director
- Academy of Neuroscience for Architecture
- 1249 F Street, Suite 222
- San Diego, CA 92101
- Phone: 619-235-0221
- E-mail: John@ANFArch.org

- Peyton A. Eggleston, M.D.
- Professor of Pediatrics and Immunology
- Johns Hopkins University
- School of Medicine
- 600 North Wolfe Street, CMSC 1102
- Baltimore, MD 21287-3200
- Phone: 410-955-5883
- Fax: 410-955-0229
- E-mail: pegglest@jhmi.edu

- Vanessa N. Elharrar, M.D., M.P.H.
- U.S. Department of Health and Human Services
- Office of the Secretary
- Office of Public Health and Science
- Office of Disease Prevention and Health Promotion
- 2208 Washington Ave #302
- Silver Spring, MD 20910
- Phone: 240-453-6112
- E-mail: velharra@jhsph.edu

- Byron A. Ellis
- Engineer
- U.S. Postal Service
- USPS Engineering
- 8403 Lee Highway
- Merrifield, VA 22030-8101
- Phone: 703-280-7954
- E-mail: Byron.A.Ellis@usps.gov

- Richard E. Ellis, J.D., R.E.H.S.
- Environmental Health Specialist
- The Ashkin Group, LLC
- Green Cleaning
- E. 2910 57th, Suite 5, # 318
- Spokane, WA 99223
- Phone: 360 280-0930
- E-mail: RichandPam_7@hotmail.com

- Michele R. Evans, Dr.P.H.
- Environmental Safety Officer
- National Institutes of Health
- Clinical Center
- Office of the Director
- Building 10, Room 62551
- Bethesda, MD 20892
- Phone: 301-496-5281
- E-mail: me55f@nih.gov

- Henry Falk, M.D., M.P.H.
- Rear Admiral, U.S. Public Health Service (Retired)
- Director, National Center for Environmental Health/Agency for Toxic Substances & Disease Registry
- Director, Coordinating Center for Environmental & Occupational Health & Injury Prevention
- Mailstop E28
- 1600 Clifton Road, NE
- Atlanta, GA 30333
- E-mail: HXF1@CDC.GOV

- Tina L. Faul, R.N., C.O.H.N.-S.
- Clinical Services Coordinator
- U.S. Department of Defense
- Occupational Health Services
- 9800 Savage Road
- Fort Meade, MD 20755
- Phone: 301-688-8598
- Fax: 301-688-3900
- E-mail: tlfaul@nsa.gov

- Ilise L. Feitshans, J.D., Sc.M.
- Author and Adjunct Faculty
- George Washington University - School of Public Health & Health Services
- Department of Occupational and Environmental Health
- 120 Warwick Road
- Haddonfield, NJ 08033
- Phone: 856-428-0605
- E-mail: ilise@prodigy.net

- Alfred J. Ferruggiaro, C.I.H.
- Industrial Hygienist
- National Institutes of Health
- Office of Research Services
- Division of Occupational Health and Safety
- Building 13, Room 3K04
- 9000 Rockville Pike
- Bethesda, MD 20892
- Phone: 301-496-3353
- Fax: 301-402-0313
- E-mail: ferrugga@mail.nih.gov

- LT Stephen T. Fields
- Industrial & Systems Engineer
- U.S. Environmental Protection Agency
- Architecture & Engineering Branch
- 1200 Pennsylvania Avenue, NW, MC: 3204R
- Washington, DC 20460
- Phone: 202-564-2418
- Fax: 202-564-8234
- E-mail: fields.stephen@epa.gov

- Nancy D. Firestone, M.Div.
- The Reverend
- Health Environment and Relationships
- 53 Numer Road
- Newport, PA 17074
- Phone: 717-576-0717
- E-mail: nfire@pa.net

- William J. Fisk, M.S., P.E.
- Staff Scientist & Department Head
- Lawrence Berkeley National Laboratory
- Indoor Environment
- 1 Cyclotron Road, MS 90-3058
- Berkeley, CA 94720
- Phone: 510-486-5910
- Fax: 510-486-6658
- E-mail: wjfisk@lbl.gov

- Susan L. Q. Flaherty
- Roha & Flaherty
- 2121 K Street, NW
- Suite 800
- Washington, DC 20037-1801
- Phone: 202-833-0033
- E-mail: slqflaherty-ngolaw@juno.com

- Caroline Freeman, M.P.H.
- Director
- U.S. Department of Labor
- Occupational Safety and Health Administration
- Office of Biological Hazards
- 200 Constitution Avenue, NW, Room N3718
- Washington, DC 20210
- Phone: 202-693-1950
- E-mail: freeman.caroline@dol.gov

- Katherine R. French, R.N., C.O.H.N.-S.
- Occupational Health Case Management Coordinator
- U.S. Department of Defense
- Occupational Health Services
- 9800 Savage Road, Suite 6404
- Fort Meade, MD 20755-6404
- Phone: 301-688-0286
- Fax: 443-479-3325
- E-mail: krfrenc@nsa.gov

- John Gallagher, R.E.E.W.
- President
- Environmental Education Foundation
- Gallagher Design & Development
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Paul L. Garbe, D.V.M., M.P.H.
- Associate Director for Science
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- Division of Environmental Hazards and Health Effects
- 1600 Clifton Road, MS E-17
- Atlanta, GA 30333
- Phone: 404-498-1829
- Fax: 404-498-1088
- E-mail: pgarbe@cdc.gov

- Suzanne M. Gaynor, Dr.P.H., R.N., M.B.A.
- Environmental Public Health Specialist
- U.S. Department of Housing and Urban Development
- Office of Healthy Homes and Lead Hazard Control
- 451 7th Street, SW, Room 3206
- Washington, DC 20410
- Phone: 202-755-1785 x127
- Fax: 202-755-1000
- E-mail: Suzanne_M._Gaynor@hud.gov

- Michael Geary
- President
- Mold Scan
- 2 Wisconsin Circle, Suite 700
- Chevy Chase, MD 20815
- Phone: 240-235-6011
- E-mail: moldscan@aol.com

- Mark D. Gibson, B.S., M.S., C.I.H.
- Industrial Hygienist
- National Institutes of Health
- Office of Research Services
- Division of Occupational Health and Safety
- Building 13, Room 3K04
- 13 South Drive, MSC 5760
- Bethesda, MD 21703-5760
- Phone: 301-496-3457
- E-mail: gibsomar@ors.od.nih.gov

- John Girman, M.S.
- Director of Center for Analysis & Studies
- U.S. Environmental Protection Agency
- Indoor Environments
- 1200 Pennsylvania Avenue, NW
- Mail Code 6609J
- Washington, DC 20460
- Phone: 202-343-9317
- Fax: 202-343-2394
- E-mail: girman.john@epa.gov

- Craig Goodrich
- Project Manager
- LB&B Associates
- O&M Contractor
- 12201 Sunrise Valley Drive
- Reston, VA 20192
- Phone: 703-648-7500
- Fax: 703-648-7527
- E-mail: lbbprojectmanager@usgs.gov

- Ronald E. Gots, M.D., Ph.D.
- Chief Executive Officer
- ICTM International Center for Toxicology
- 2301 Research Boulevard
- Suite 210
- Rockville, MD 20850-3204
- Phone: 301-519-0300
- Fax: 301-519-1307
- E-mail: regots@ictm.com

- Brian Gumm
- Writer and Researcher
- Alliance for Healthy Homes
- 227 Massachusetts Avenue, NE, Suite 200
- Washington, DC 20002
- Phone: 202-543-1147
- Fax: 202-543-4466
- E-mail: bgumm@afhh.org

- Vijay Gupta, P.E.
- Senior Mechanical Engineer
- U.S. General Services Administration
- Office of the Chief Architect
- 1800 F Street, NW, Suite 3341
- Washington, DC 20405
- Phone: 202-501-0628
- Fax: 202-501-3393
- E-mail: vijay.gupta@gsa.gov

- Sandra H. Handon, M.E.
- Environmental Engineer
- District of Columbia Department of Health
- Air Quality Division
- 51 N Street, 5th Floor
- Washington, DC 20001
- Phone: 202-535-1722
- Fax: 202-535-1371
- E-mail: sandra.handon@dc.gov

- Bryan D. Hardin, Ph.D.
- GlobalTox, Inc.
- 33 Office Park Road
- 4A PMB 344
- Hilton Head Island, SC 29928
- Phone: 843-363-9466
- Fax: 843-363-9465
- E-mail: bhardin@globaltox.com

- David B. Hattis, M.Arch.
- President
- Building Technology Inc.
- 1109 Spring Street
- Silver Spring, MD 20910
- Phone: 301-588-5020
- Fax: 301-587-5154
- E-mail: dbhattis@bldgtechnology.com

- Vickie R. Hawkins, M.S., CIE, CIH
- Industrial Hygienist
- U.S. Army Center for Health Promotion and Preventive Medicine
- 5158 Blackhawk Road
- MCHB-TS-OFS
- APG, MD 21010-5403
- Phone: 410-436-3118
- Fax: 410-436-5471
- E-mail: vickie.hawkins@amedd.army.mil

- Paul D. Hawver
- Mechanical Engineering Technician
- National Institutes of Health
- Office of Research Facilities
- Division of Policy and Program Assessment
- Construction Oversite Group
- 9000 Rockville Pike, Building 13, Room 201
- Bethesda, MD 20892
- Phone: 301-402-5140
- Fax: 301-496-7172
- E-mail: Paul_Hawver@nih.gov

- Dave H. Haynes, B.S.E.H.
- Industrial Hygienist
- Department of Army
- EOIR Contractor, Safety Office
- 10221 Burbeck Road
- Fort Belvoir, VA 22060-5806
- Phone: 703-704-3682
- Fax: 703-704-3431
- E-mail: david.haynes@nvl.army.mil

- Jerry Hershovitz
- Acting Deputy Director/Associate Director for Program Development
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- Division of Emergency and Environmental Health Services
- 4770 Buford Highway, NE, Mail Stop F-30
- Atlanta, GA 30341-3717
- Phone: 770-488-4542
- Fax: 770-488-4820
- E-mail: JHershovitz@cdc.gov

- Jonathan Herz, A.I.A.
- Architect
- Innovative Workplaces Division
- GSA Office of Governmentwide Policy
- 1800 F Street NW, (MPW)
- Washington, DC 20405
- Phone: 202-501-3476
- E-mail: jonathan.herz@gsa.gov

- Marian L. Heyman, M.P.H.
- Epidemiologist/Industrial Hygienist
- Connecticut Department of Public Health
- Environmental & Occupational Health Assessment
- 410 Capitol Avenue, MS# 11CHA
- P.O. Box 340308
- Hartford, CT 06134-0308
- Phone: 860-509-7742
- Fax: 860-509-7785
- E-mail: marian.heyman@po.state.ct.us

- Daniel L. Hightower, A.I.A.
- Director
- BBH Design
- Programming and Planning
- P.O. Box 12697
- Research Triangle Park, NC 27709
- Phone: 919-460-6700
- Fax: 919-460-6733
- E-mail: dhightower@bbh-design.com

- James E. Hill, Ph.D.
- National Institute of Standards and Technology
- 100 Bureau Drive, Stop 8600
- Building 226, Room B216
- Gaithersburg, MD 20899
- Phone: 301-975-4032
- Fax: 301-975-4032
- E-mail: james.hill@nist.gov

- Michael Hodgson, M.D.
- U.S. Department of Veterans Affairs
- 810 Vermont Avenue
- Washington, DC 20201
- E-mail: muh7@va.gov

- Deana J. Holmes
- Scientist
- U.S. Department of Labor
- Occupational Safety and Health Administration
- 200 Constitution Avenue, NW, Room N3718
- Washington, DC 20210
- Phone: 202-639-1950
- E-mail: holmes.deana@dol.gov

- Ernie B. Hood
- Reporter
- National Institutes of Health
- National Institute of Environmental Health Sciences
- P.O. Box 12233
- Research Triangle Park, NC 27709
- Phone: 919-544-5700
- Fax: 919-544-6992
- E-mail: bkthrough@aol.com

- Donald R. Horn, A.I.A.
- Director, Sustainable Design Program
- U.S. General Services Administration
- Office of Applied Science
- 1800 F Street, NW
- Room 4046
- Washington, DC 20405
- Phone: 202-501-4525
- Fax: 202-501-3203
- E-mail: donald.horn@gsa.gov

- Glenn C. Hourahan, P.E.
- VP, Research & Technology
- Air Conditioning Contractors of America
- 2800 Shirlington Road, Suite 300
- Arlington, VA 22206
- Phone: 703-824-8865
- E-mail: glenn.hourahan@acca.org

- Jennifer M. Houser
- Industrial Hygienist
- U.S. Department of Defense
- Washington Headquarters Services
- Defense Facilities Directorate
- 1155 Defense Pentagon
- Washington, DC 20301-1155
- Phone: 703-693-3683
- Fax: 703-614-9671
- E-mail: Jennifer.Houser@whs.mil

- Keith Howell, Ph.D.
- Associate Dean for Research
- University of North Carolina at Greensboro
- School Health and Human Performance
- 229 HHP Building
- Greensboro, NC 27402
- Phone: 336-256-2475
- Fax: 336-334-3238
- E-mail: howellk@uncg.edu

- Allen L. Ingling, R.I.A.Q.M.
- Environmental Education Foundation
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- David E. Jacobs, Ph.D.
- U.S. Department of Housing and Urban Development
- Community Planning and Development
- 451 7th Street, SW, Room 7208
- Washington, DC 20410
- Phone: 202-708-0614 x5647
- E-mail: david_e._jacobs@hud.gov

- Dawn Jacobson, M.D., M.P.H.
- Senior Clinical Advisor
- U.S. Department of Health and Human Services
- Office of Public Health and Science
- Office of Disease Prevention and Health Promotion
- 1101 Wootton Parkway
- Suite LL100, Room 120
- Rockville, MD 20852
- Phone: 240-453-8251
- Fax: 240-453-8281
- E-mail: djacobso@osophs.dhhs.gov

- Philip P. Jalbert
- Executive Secretary CIAQ
- U.S. Environmental Protection Agency
- Indoor Environments Division
- 1200 Pennsylvania Avenue, NW
- Washington, DC 20460
- Phone: 202-343-9431
- E-mail: jalbert.philip@epa.gov

- Alison K. Johnson
- Chair
- Chemical Sensitivity Foundation
- Author, Video Producer/Director
- 3 Larrabee Farm Road
- Brunswick, ME 04011
- Phone: 207-725-8570
- E-mail: alisonjmcs@aol.com

- Barbara A. Jones, M.S.P.H., M.S.W.
- DHHS Emerging Leader
- U.S. Department of Health and Human Services
- Office of the Secretary
- Office of Public Health and Science
- Office of Disease Prevention and Health Promotion
- 1101 Wootton Parkway, Suite LL100
- Rockville, MD 20852
- Phone: 240-453-8271
- E-mail: bjones2@osophs.dhhs.gov

- Julie B. Kacergis, C.I.H.
- Industrial Hygienist
- Smithsonian Institution
- Office of Safety and Environmental Management
- 750 9th Street, NW
- Suite 9100
- Washington, DC 20013-7012
- Phone: 202-275-0734
- Fax: 202-275-0746
- E-mail: kacergisj@si.edu

- Kevin Kampschroer
- U.S. General Services Administration
- Public Buildings Service
- Research and Expert Services
- 1800 F Street, NW, 4015
- Washington, DC 20405-0001
- Phone: 202-501-4411
- Fax: 202-219-2072
- E-mail: kevin.kampschroer@gsa.gov

- Adam Kautz
- K9 Dog Handler
- BCRSK9 Mold Detection Service
- K9 Mold Inspection Service
- P.O. Box 508
- New Windsor, MD 21776
- Phone: 888-289-0162
- Fax: 410-635-6020
- E-mail: bobcat1088@juno.com

- Joseph D. Kelly, M.D., M.S.
- National Institutes of Health
- Office of Research Services
- Division of Occupational Health and Safety
- Building 13, Room 3K04
- Bethesda, MD 20892
- Phone: 301-496-3353
- E-mail: kellyjoe@mail.nih.gov

- Tom Kelly
- Director
- U.S. Environmental Protection Agency
- Indoor Environments
- 1200 Pennsylvania Avenue, NW
- Mail Code 6609J
- Washington, DC 20460
- Phone: 202-343-9370
- Fax: 202-343-2394
- E-mail: kelly.tom@epa.gov

- Woodie Kessel, M.D., M.P.H.
- Assistant Surgeon General
- U.S. Department of Health and Human Services
- Office of the Secretary
- Office of Public Health and Science
- Office of Disease Prevention and Health Promotion
- 1101 Wootton Parkway LL100
- Rockville, MD 20852
- Phone: 240-453-8256
- E-mail: wkessel@osophs.dhhs.gov

- Naseeb Kibria
- Manager, Childhood Asthma Programs
- American Lung Association
- Research and Program Services
- 1150 18th Street, NW, Suite 900
- Washington, DC 20036
- Phone: 202-785-3355
- Fax: 202-452-1805
- E-mail: nkibria@lungusadc.org

- Larainne G. Koehler
- Radon & Indoor Air Coordinator
- U.S. Environmental Protection Agency - Region 2
- Radiation & Indoor Air Branch
- 290 Broadway
- New York, NY 10007-1866
- Phone: 212-637-4005
- Fax: 212-637-4942
- E-mail: koehler.larainne@epa.gov

- Pamela Kogan
- Program Analyst
- U.S. Environmental Protection Agency
- Office of Radiation and Indoor Air
- 1200 Pennsylvania Avenue, NW
- Mail Code 6609J
- Washington, DC 20460
- Phone: 202-343-9564
- E-mail: kogan.pamela@epa.gov

- Laura Kolb
- U.S. Environmental Protection Agency
- Indoor Environment
- 10818 Orchard Street
- Fairfax, VA 22030
- Phone: 202-343-9438
- Fax: 202-343-2394
- E-mail: kolb.laura@epa.gov

- Tracy Kolian
- 800 I Street, NW
- Washington, DC 20001
- Phone: 202-777-2435
- E-mail: tracy.kolian@apha.org

- Brian Kong, P.E.
- National Institutes of Health
- 13 South Drive, Room 210
- Bethesda, MD 20892
- Phone: 301-402-4742
- E-mail: sungbriankong@yahoo.com

- Sharon N. Kramer
- Realtor
- Mycotic Disease Awareness/MDAwareness
- P.O. Box 676327
- Rancho Santa Fe, CA 92067
- Phone: 760-822-8026
- E-mail: snk1955@aol.com

- Kathleen Kreiss, M.D.
- Branch Chief
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- Division of Respiratory Disease Studies
- Field Studies Branch
- 1095 Willowdale Road, MS 2800
- Morgantown, WV 26505
- Phone: 304-285-5751
- Fax: 304-285-5820
- E-mail: kxk2@cdc.gov

- Satish Kumar, Ph.D.
- Scientist
- Lawrence Berkeley National Laboratory
- Energy Analysis Program
- 901 D Street, SW, Suite 950
- Washington, DC 20024
- Phone: 202-646-7953
- Fax: 202-646-7800
- E-mail: SKumar@lbl.gov

- Celia Kuperszmid Lehrman
- Senior Editor
- Consumers Union
- Consumer Reports
- 101 Truman Avenue
- Yonkers, NY 10703
- Phone: 914-378-2012
- E-mail: lehrce@consumer.org

- Christopher S. Lafferty
- U.S. Environmental Protection Agency
- 109 TW Alexander Drive
- Mail Drop C60405
- Research Triangle Park
- Durham, NC 27711
- Phone: 919-541-1957
- Fax: 919-541-2570
- E-mail: lafferty.shawn@epa.gov

- Charles J. Lamielle
- National Center for Environmental Health Strategies
- 1100 Rural Avenue
- Voorhees, NJ 08043
- Phone: 856-429-5358
- E-mail: ncehs@ncehs.org

- Mary D. Lamielle
- Executive Director
- National Center for Environmental Health Strategies
- 1100 Rural Avenue
- Voorhees, NJ 08043
- Phone: 856-429-5358
- E-mail: ncehs@ncehs.org

- Stephanie A. Lamster
- Environmental Protection Specialist
- U.S. Environmental Protection Agency
- Indoor Environments Division
- 1200 Pennsylvania Avenue, NW
- Mail Code 6609J
- Washington, DC 20460
- Phone: 202-343-9614
- Fax: 202-343-2393
- E-mail: Lamster.stephanie@epa.gov

- Michael J. Langone
- Building Management Specialist
- U.S. Department of Defense
- Washington Headquarters Services
- Real Estate and Facility
- 1155 Defense Pentagon
- RDF 1J702
- Washington, DC 20301-1155
- Phone: 703-695-7968
- Fax: 703-601-2296
- E-mail: michael.langone@whs.mil

- Stephen Langone
- Building Operations Specialist
- U.S. Geological Survey
- Facilities Maintenance Branch
- 12201 Sunrise Valley Drive
- Reston, VA 20192
- Phone: 703-648-7502
- Fax: 703-648-7527
- E-mail: slangone@usgs.gov

- Kiyoung Lee
- Assistant Professor
- University of Kentucky
- Environmental Health
- 121 Washington Avenue
- Lexington, KY 40536
- Phone: 859-257-5678 x82243
- E-mail: kiyoung@uky.edu

- Marc Leftwich, R.I.A.Q.M.
- Environmental Education Foundation
- AMT Mold Testing & Consulting
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Bill Lehmann, R.I.A.Q.M.
- National Sales
- Environmental Education Foundation
- Point Source Solution
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Bob Lehmann, R.I.A.Q.M.
- National Marketing
- Environmental Education Foundation
- Point Source Solution
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Monique Lester, M.P.H.
- Environmental Scientist
- U.S. Environmental Protection Agency
- 2301 Glenallen Avenue
- Apartment 310
- Silver Spring, MD 20906
- Phone: 202-564-1342
- E-mail: lester.monique@epa.gov

- Hal Levin, B.Arch.
- Building Ecology Research Group
- 2548 Empire Grade
- Santa Cruz, CA 95060
- Phone: 831-425-3946
- Fax: 831-426-6522
- E-mail: hal.levin@buildingecology.com

- James S. Lewis, P.E.
- Mechanical Engineer
- National Institutes of Health
- Division of Policy & Program Assessment
- Building 13, Room 201, 13 South Drive
- Bethesda, MD 20802
- Phone: 301-435-2047
- Fax: 301-496-7172
- E-mail: lewisj@mail.nih.gov

- James W. Lewis, C.I.H., C.S.P.
- Program Manager
- Maryland Department of the Environment
- Air & Radiation Management Administration
- 1800 Washington Boulevard, Suite 750
- Baltimore, MD 21230
- Phone: 410-537-3300
- Fax: 410-537-3198
- E-mail: jlewis@mde.state.md.us

- Kevin M. Leyden, Ph.D.
- Director
- West Virginia University
- Institute for Public Affairs
- 301-B Woodburn Hall
- Morgantown, WV 26506-6317
- Phone: 304-293-5432
- E-mail: Kleyden@wvu.edu

- Patricia Liegey
- Occupational Safety and Health Program Mgr.
- U.S. Department of Homeland Security
- Citizen and Immigration Service
- 20 Massachusetts Avenue, NW
- Washington, DC 20529
- Phone: 202-272-1354
- Fax: 202-272-1352
- E-mail: patricia.liegey@dhs.gov

- Ed N. Light, C.I.H.
- Building Dynamics
- 1216 Ashton Road
- Ashton, MD 20861
- Phone: 301-924-6264
- Fax: 703-450-4649
- E-mail: Elight@building-dynamics.com

- Maureen K. Little, M.P.H.
- New York City Department of Health and Mental Hygiene
- 253 Broadway, Room 402, CN-34C
- New York, NY 10007
- Phone: 212-227-3740
- E-mail: mlittle@health.nyc.gov

- Vivian Loftness, M. Arch.
- Professor
- Carnegie Mellon University
- Department of Architecture
- Pittsburgh, PA 15213-3890
- Phone: 412-268-1539
- E-mail: loftness@andrew.cmu.edu

- Boyd Long, R.I.A.Q.M.
- Environmental Education Foundation
- Medallion Healthy Homes
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Rebecca Love
- Associate
- National Environmental Education and Training Foundation
- Health & Environment Programs
- 1707 H Street, NW
- Washington, DC 20006
- Phone: 202-261-6475
- E-mail: love@neetf.org

- Athanasia I. Mantzouranis
- Team Leader
- U.S. Food and Drug Administration
- ORPS/Division of Engineering Services
- 5630 Fishers Lane, Room 2051A
- Rockville, MD 20857
- Phone: 301-827-9811
- Fax: 301-827-7019
- E-mail: athanasia.mantzouranis@fda.gov

- Larry L. Marcum, J.D., M.P.A.
- Manager Government Affairs
- National Environmental Health Association
- R&D/GA
- 720 S Colorado Blvd., South Tower, Suite 970
- Denver, CO 80246
- Phone: 303-756-9090 x303
- Fax: 303-691-9490
- E-mail: LMARCUM@neha.org

- Jayne Mardock
- American Lung Association
- National Policy and Advocacy
- 1150 18th Street, NW, Suite 900
- Washington, DC 20912
- Phone: 202-785-3355
- Fax: 202-452-1805
- E-mail: jmardock@lungusadc.org

- Michelle L. Markley
- Safety Training Program Manager
- National Institutes of Health
- Office of Research Services
- Division of Occupational Health and Safety
- 13 South Drive, MSC 5760
- Bethesda, MD 20892
- Phone: 301-451-5824
- E-mail: mmark@mail.nih.gov

- Marcia F. Marks, A.C.S.W.
- Environmental-Health/Policy Consultant
- 5317 Cardinal Court
- Bethesda, MD 20816-2908
- Phone: 301-229-6466
- Fax: 301-320-3189
- E-mail: fragermark@mindspring.com

- Joanna M. Matheson, Ph.D.
- Toxicologist
- U.S. Consumer Product Safety Commission
- Health Sciences Division
- 4330 East West Highway
- Bethesda, MD 20814
- Phone: 301-504-7043
- Fax: 301-504-0079
- E-mail: jmatheson@cpsc.gov

- CDR Wade B. McConnell, M.S.E.H.
- Chief
- U.S. Coast Guard
- Environmental Health Division
- Office of Health and Safety, G-WKS-3
- 2100 2nd Street SW
- Washington, DC 20593
- Phone: 202-267-1388
- Fax: 202-267-4355
- E-mail: wmcconnell@comdt.uscg.mil

- Richard A. McCrone
- Senior Operations Engineer
- U.S. Department of Veterans Affairs
- 810 Vermont Avenue
- Washington, DC 20420
- Phone: 202-273-5880
- E-mail: Richard.McCrone@hq.med.va.gov

- Leyla E. McCurdy, M.Phil.
- Senior Director
- National Environmental Education and Training Foundation
- Health & Environment Programs
- 1707 H Street, NW, Suite 900
- Washington, DC
- Phone: 202-261-6488
- E-mail: mccurdy@neetf.org

- Stephen A. McFadden, M.S.
- Independent Scientific Research Advocates
- 5521 Greenville Avenue, #104-608
- Dallas, TX 75206
- Phone: 301-897-9614
- E-mail: isra@dfwonline.net

- Terry M. McFarland, R.N., C.O.H.N.-S., C.I.A.Q.P.
- Industrial Hygienist
- National Security Agency
- Occupational Health & Safety
- 9800 Savage Road, Suite 6404
- Fort Meade, MD 20755-6000
- Phone: 301-688-7824
- Fax: 301-688-2423
- E-mail: tlmcfa1@nsa.gov

- Paul W. McHam
- CMR, Mold Across America
- Consulting Board
- P.O. Box 770991
- Lakewood, OH 44107
- Phone: 877-280-6653
- Fax: 216-221-1942
- E-mail: info@moldacrossamerica.org

- Farhad Memarzadeh, Ph.D.
- Director
- National Institutes of Health
- Division of Policy & Program Assessment
- Building 13, Room 201
- Bethesda, MD
- Phone: 301-435-8746
- E-mail: memarzaf@ors.od.nih.gov

- Mark J. Mendell, Ph.D.
- Epidemiologist
- Lawrence Berkeley National Laboratory
- Indoor Environment Department
- 1 Cyclotron Road, MS 90-3058
- Berkeley, CA 94720
- Phone: 510-486-5762
- Fax: 510-486-6658
- E-mail: mjmendell@lbl.gov

- Suzanne Mikuljan
- Public Health Sanitarian
- Nassau County Department of Health
- 240 Old Country Road
- Mineola, NY 11501
- Phone: 516-571-3232
- Fax: 516-571-3828
- E-mail: eessjbo@health.co.nassau.ny.us

- Victor Miller, R.Ph.
- Information Specialist
- U.S. Environmental Protection Agency
- Health Effects Division
- 9300 Brookville Road
- Silver Spring, MD 20910
- Phone: 301-346-6501
- Fax: 703-305-5147
- E-mail: cri@ix.netcom.com

- M. Deborah Millette, M.P.H.
- Assistant Director for Program Development
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- Division of Emergency and Environmental Health Services
- 4770 Buford Highway, NE, Mail Stop F-30
- Atlanta, GA 30341-3717
- Phone: 770-488-7177
- Fax: 770-488-4820
- E-mail: DMillette@cdc.gov

- Wesley E. Mills, R.E.H.S.
- Environmental Health Specialist
- United States Congress
- Office of Attending Physician
- B-344 Rayburn HOB
- Washington, DC 20015
- Phone: 202-225-7993
- Fax: 202-226-8718
- E-mail: wmills@aoc.gov

- Clifford S. Mitchell, M.S., M.D., M.P.H.
- Associate Professor Environmental Health Sciences
- Johns Hopkins University
- Division of Occupational & Environmental Health
- School of Hygiene & Public Health
- Room 7041
- 615 North Wolfe Street
- Baltimore, MD 21205
- Phone: 410-955-4076
- Fax: 410-955-1811
- E-mail: cmitchel@jhsph.edu

- Daniel L. Moberly
- IAQ Resident Practitioner
- Association of School Business Officials
- P.O. Box 1418
- Ocean Shores, WA 98569
- Phone: 360-289-8040
- E-mail: dmoberly2003@yahoo.com

- Ronald L. Moolenaar, M.D., M.P.H.
- Medical Epidemiologist
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- 1600 Clifton Road, NE, MS E-17
- Atlanta, GA 30333
- Phone: 404-498-1017
- E-mail: rlm8@cdc.gov

- Rebecca L. Morley, M.P.P.
- Executive Director
- National Center for Healthy Housing
- 10227 Woncopin Circle, Suite 100
- Columbia, MD 21045
- Phone: 410-772-2774
- E-mail: rmorley@centerforhealthyhousing.org

- Cole Murphy, P.E.
- Senior Mechanical Engineer
- National Institutes of Health
- Office of Research Facilities
- Division of Capital Project Management
- McKissack & McKissack
- Building 10, Room B1C27A
- Bethesda, MD 20892-1057
- Phone: 301-402-5141
- E-mail: cole_murphy@nih.gov

- CAPT Ernestine W. Murray, R.N., B.S.N., M.A.S.
- Senior Health Policy Analyst
- Agency for Healthcare Research and Quality
- Center for Outcomes and Evidence
- 540 Gaither Road
- Rockville, MD 20850-6649
- Phone: 301-427-1630
- E-mail: emurray@ahrq.gov

- Ian Nazarenko, R.I.A.Q.M., R.M.I.
- Environmental Consultant
- Environmental Education Foundation
- EMCOR Facilities Services
- 320 23rd Street South, Suite 100
- Arlington, VA 22202
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Luke Nicholson, P.E.
- Adjunct Professor
- University of Florida
- M.E. Rinker School of Building Construction
- 304 Rinker Hall, P.O. Box 115703
- Gainesville, FL 32611-5703
- Phone: 828-230-6664
- E-mail: luken@ufl.edu

- Shirley M. Niemeyer, Ph.D.
- Extension Specialist
- Cooperative Extension-USDA
- University, Department UNL
- Room 205, HE Building, East Campus, UNL
- Lincoln, NE 68583-0804
- Phone: 402-472-6319
- Fax: 402-472-0640
- E-mail: sniemeyer2@unl.edu

- Janice E. Nolen, M.S.
- Director, National Policy
- American Lung Association
- 1150 18th Street, NW, Suite 900
- Washington, DC 20036
- Phone: 202-785-3355
- Fax: 202-452-1805
- E-mail: jnolen@lungusadc.org

- John B. Ochwat
- Public Health Sanitarian II
- Nassau County Department of Health
- 240 Old Country Road
- Mineola, NY 11501
- Phone: 516-571-3232
- Fax: 516-571-3828
- E-mail: eessjbo@health.co.nassau.ny.us

- Elena Page, M.D., M.P.H.
- Medical Officer
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- 4676 Columbia Parkway, Mailstop R-10
- Cincinnati, OH 45226
- Phone: 513-458-7144
- E-mail: epage@cdc.gov

- Ju-Hyeong Park, Sc.D., C.I.H.
- Senior Service Fellow
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- Division of Respiratory Disease Studies
- 1095 Willowdale Road
- Morgantown, WV 26505
- Phone: 304-285-5967
- Fax: 304-285-5820
- E-mail: gzp8@cdc.gov

- Paul Parrish, M.D.
- Occupational Medicine Consultant
- U.S. Air Force Institute for Operational Health
- Health and Safety Division
- AFIOH/RSH
- 2513 Kennedy Circle
- Brooks City-Base, TX 78235-5116
- Phone: 210-536-6115
- E-mail: Paul.Parrish@brooks.af.mil

- Sharon L. Pate, M.S., C.H.M.M.
- Industrial Hygienist
- Blanchfield Army Community Hospital
- PM, IHS
- 6903 Desert Storm Avenue
- Fort Campbell, KY 42223
- Phone: 270-798-8695
- E-mail: sharon.pate@se.amedd.army.mil

- Priti R. Patel, M.D., M.P.H.
- Maryland Department of Health and Mental Hygiene
- 201 W. Preston Street, Room 317
- Baltimore, MD 21201
- Phone: 410-767-5597
- Fax: 410-333-5233
- E-mail: ppatel@cdc.gov

- Henry F. Pauley, C.I.H.
- Senior Officer Industrial Hygiene
- Amtrak
- Environmental Health & Safety
- 60 Massachusetts Avenue, NE
- Washington, DC 20002
- Phone: 202-906-3271
- Fax: 202-906-3721
- E-mail: pauleyh@amtrak.com

- Terri A. Pearce, Ph.D.
- Industrial Hygienist
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- Division of Respiratory Disease Studies
- Field Studies Branch
- 1095 Willowdale Road, MS 2800
- Morgantown, WV 26505
- Phone: 304-285-6211
- Fax: 304-285-5820
- E-mail: TPearce@cdc.gov

- Nicholas Peneff, Dr.P.H., C.I.H.
- Public Health & Safety, Inc.
- 112 Lawn Place
- Rockford, IL 61104
- Phone: 815-961-9239
- Fax: 815-961-9242
- E-mail: phsinc3@prodigy.net

- CAPT Edward A. Pfister, R.E.H.S.
- Environmental Compliance Officer
- National Institutes of Health
- Office of Research Facilities Development and Operations
- Division of Environmental Protection
- Building 13, Room 2W64, MSC 5746
- 9000 Rockville Pike
- Bethesda, MD 20892-5746
- Phone: 301-496-7775
- Fax: 301-480-8056
- E-mail: pfistere@mail.nih.gov

- Melanie S. Pickett, M.P.H.
- CDC/ATPM Research Fellow
- Centers for Disease Control and Prevention
- National Center for Health Statistics
- Division of Health and Nutrition Examination Surveys
- 3311 Toledo Road, Room 4216
- Hyattsville, MD 20782
- Phone: 301-458-4809
- E-mail: mpickett@cdc.gov

- Thomas Platts-Mills, M.D., M.P.H.
- University of Virginia Health System
- P.O. Box 801355, Room 5086, MR-4
- Charlottesville, VA 22908
- Phone: 434-924-2209
- E-mail: tap2z@virginia.edu

- Lawrence A. Plumlee, M.D.
- Editor
- American Academy of Environmental Medicine
- The Environmental Physician
- 5717 Beech Avenue
- Bethesda, MD 20817-2563
- Phone: 301-897-9614
- E-mail: laplumlee@pol.net

- Doug Podolsky
- Senior Editor
- Consumer Reports
- 1666 Connecticut Ave., NW, Suite 310
- Washington, DC 20009
- Phone: 202-462-6262
- E-mail: dpodolsky@consumer.org

- Joseph T. Ponessa, Ph.D.
- Professor, Indoor Environments & Health
- Rutgers Cooperative Extension
- Department of Human Ecology
- 71 Lipman Drive
- New Brunswick, NJ 08901
- Phone: 732-932-9349
- Fax: 732-932-3126
- E-mail: ponessa@aesop.rutgers.edu

- Marc Pressman, C.M.R., C.E.M., C.M.A., C.T.S.
- Certified Environmental Inspector
- The Original Basement Rx Waterproofing Company -- Mold Remediation
- 2951 Philmont Avenue
- Huntingdon Valley, PA 19006
- Phone: 215-913-4400

- Bradley E. Provancha, S.E.S., C.H.E., C.P.M.
- Deputy Director
- U.S. Department of Defense
- Washington Headquarters Services
- Defense Facilities Directorate, Room 4A111
- The Pentagon
- Washington, DC 20301-1155
- Phone: 703-697-7241
- Fax: 703-695-9330
- E-mail: bradley.provancha@whs.mil

- Michael A. Purviance
- Safety and Occupational Health Manager
- U.S. Office of Personnel Management
- Safety and Facilities Services
- 113 Oaklawn Road
- Stafford, VA 22554
- E-mail: mpurvian@opm.gov

- Anita Pustelnik, M.H.S., C.I.H.
- Akva, Inc.
- 2506 Poplar Drive
- Baltimore, MD 21207
- Phone: 410-944-3309
- Fax: 410-944-1907
- E-mail: anita@akva-inc.com

- John M. Putnam, C.T.A.B., C.I.E., C.M.R.
- CEO/CTO
- EDDI
- Environmental Technology & Remediation
- 168 Magnolia Road
- Sterling, VA 20164
- Phone: 703-450-9460, 703-819-9460
- Fax: 703-406-8807
- E-mail: edyn@earthlink.net

- Wade A. Raines, P.E.
- Team Leader
- U.S. Postal Service
- Engineering, Maintenance Policies
- 8403 Lee Highway
- Merrifield, VA 22082-8101
- Phone: 703-280-7896
- E-mail: wade.a.raines@usps.gov

- Carol Rao, Sc.D.
- Health Scientist
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- 200 Independence Avenue, MS P-12
- Washington, DC 20201
- Phone: 202-401-0879
- E-mail: cnr3@cdc.gov

- CAPT Edward H. Rau, M.S., R.S., C.H.S.P.
- Environmental Health Officer
- National Institutes of Health
- Office of Research Facilities Development and Operations
- Division of Environmental Protection
- 13 South Drive, Room 2W64, MSC 5746
- Bethesda, MD 20892-5746
- Phone: 301-496-7775
- Fax: 301-480-8056
- E-mail: raue@mail.nih.gov

- CAPT Stephen C. Redd, M.D.
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- Division of Environmental Hazards and Health Effects
- 1600 Clifton Road
- MS-E17
- Atlanta, GA 30333
- E-mail: sredd@cdc.gov

- Thomas A. Reed
- Maintenance Engineering Analyst
- U.S. Postal Service
- 8403 Lee Highway
- Merryfield, VA 22082
- Phone: 703-280-7387
- Fax: 703-280-8404
- E-mail: thomas.a.reed@usps.gov

- Audrey S. Regan, M.P.P.
- Program Administrator
- Maryland Department of Health and Mental Hygiene
- Center for Maternal and Child Health
- 201 W. Preston Street, Room 317
- Baltimore, MD 21201
- Phone: 410-767-3431
- Fax: 410-333-5233
- E-mail: aregan@dhmh.state.md.us

- Rick Regan, R.I.A.Q.M.
- Environmental Education Foundation
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Rip Rice, Ph.D., R.I.A.Q.M.
- Executive VP of Environmental Compliance
- Environmental Education Foundation
- SCO Medallion Healthy Homes
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 301-774-9133
- E-mail: info@enviro-ed.org

- Dena Richardson
- Mechanical Engineer
- U.S. Department of State
- OBO/PE/DE/MEB SA-6
- Washington, DC 20522-0611
- Phone: 703-516-1622
- E-mail: richardsond@state.gov

- Denise C. Richardson, C.I.H.
- Industrial Hygienist
- U.S. Postal Service Headquarters
- Safety Performance Management
- 475 L’Enfant Plaza, SW
- Washington, DC 20260
- Phone: 202-268-3686
- Fax: 202-268-2206
- E-mail: denise.c.richardson@usps.gov

- Michael J. Richen, C.I.H.
- Indoor Air Quality Coordinator
- Boulder County Public Health
- Environmental Health Division
- 3450 Broadway
- Boulder, CO 80304
- Phone: 303-441-1566
- Fax: 303-441-1468
- E-mail: mrichen@co.boulder.co.us; m.richen@comcast.net

- James Rifenburg
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- Division of Environmental Hazards and Health Effects
- 1600 Clifton Road, MS E-17
- Atlanta, GA 30333
- Phone: 404-498-1021
- E-mail: jar4@cdc.gov

- Lloyd C. Roberts
- Safety and Occupational Health Manager
- U.S. Department of Defense
- Defense Contract Management Agency
- Human Resources
- 6350 Walker Lane, Suite 300
- Alexandria, VA 22310-1504
- Phone: 703-428-1333
- Fax: 703-428-1504
- E-mail: lloyd.roberts@dcma.mil

- CAPT Sven E. Rodenbeck, Sc.D., P.E., BCEE
- Coordinator, Surgeon General’s Workshop on Healthy Indoor Environment
- Agency for Toxic Substances and Disease Registry
- Division of Health Assessment and Consultation
- Mailstop E-32
- 1600 Clifton Road, NE
- Atlanta, GA 30333
- Phone: 404-498-0439
- E-mail: srodenbeck@cdc.gov

- Ian Rosenblum
- Industrial Hygienist
- U.S. Department of the Interior
- National Business Center
- 1849 C Street, NW, Room 1222-MIB
- Washington, DC 20240-0001
- Phone: 202-208-5795
- Fax: 202-208-3777
- E-mail: Ian_M_Rosenblum@nbc.gov

- Betsy F. Rosenfeld, J.D.
- Deputy Regional Health Administrator - Region I (New England)
- U.S. Department of Health and Human Services
- Office of the Secretary
- Office of Public Health and Science
- JFK Federal Building, Suite 2100
- Boston, MA 02203
- Phone: 617-565-1505
- Fax: 617-565-1491
- E-mail: brosenfeld@osophs.dhhs.gov

- Don T. Ryan, M.U.R.P.
- Executive Director
- Alliance for Healthy Homes
- 227 Massachusetts Avenue, NE, Suite 200
- Washington, DC 20002
- Phone: 202-543-1147
- Fax: 202-543-4466
- E-mail: dryan@afhh.org

- DeAnn Ryberg, M.P.H.
- Epidemiologist
- Centers for Disease Control and Prevention
- National Center for Environmental Health
- Division of Environmental Hazards and Health Effects
- Air Pollution and Respiratory Health Branch
- 1600 Clifton Road, NE, MS E-17
- Atlanta, GA 30333
- Phone: 404-498-2144
- Fax: 404-498-1088
- E-mail: ayx3@cdc.gov

- LCDR Nancy M. Sahakian, M.D., M.P.H.
- Medical Officer
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- Division of Respiratory Disease Studies
- 1095 Willowdale Road, MS-2800
- Morgantown, WV 26505
- Phone: 304-285-6383
- E-mail: nks6@cdc.gov

- Robert Salas, R.A.
- Project Executive
- Hammes Company
- 4900 Seminary Road, Suite 670
- Alexandria, VA 22311
- Phone: 703-998-2400
- Fax: 703-998-2040
- E-mail: bsalas@hammesco.com

- Lori E. Saltzman, M.S.
- Director
- U.S. Consumer Product Safety Commission
- Division of Health Sciences
- 4330 East West Highway
- Bethesda, MD
- Phone: 301-504-7238
- E-mail: lsaltzman@cpsc.gov

- Jonathan M. Samet, M.D.
- Professor and Chairman
- Johns Hopkins University
- Department of Epidemiology
- Bloomberg School of Public Health
- 615 North Wolfe Street, Suite W6041
- Baltimore, MD 21205
- Phone: 410-955-3286
- Fax: 410-614-0467
- E-mail: jsamet@jhsph.edu

- Ken G. Sandler
- Co-Chair
- U.S. Environmental Protection Agency
- Green Building Work Group
- Mail Code 6609J
- 1200 Pennsylvania Avenue, NW
- Washington, DC 20460
- Phone: 202-343-6907
- Fax: 202-343-2394
- E-mail: sandler.ken@epa.gov

- Steve P. Sauer
- Editor
- Indoor Environment Connections
- 12339 Carroll Avenue
- Rockville, MD 20852
- Phone: 301-230-9606
- Fax: 301-230-9631
- E-mail: iecnews@aol.com

- Paula Schenck, M.P.H.
- Assistant Director, Center for Indoor Environments and Health
- University of Connecticut Health Center
- Division of Occupational and Environmental Medicine
- 263 Farmington Avenue
- Farmington, CT 06013
- Phone: 860-679-2368
- Fax: 860-679-1349
- E-mail: schenck@nso2.uchc.edu

- Hans W. Schleibinger, Ph.D.
- Senior Research Officer
- Indoor Environment Research Program
- 1200 Montreal Road, M-24
- Ottawa, ON K1A 0R6
- Canada
- Phone: 613-993-9702
- Fax: 613-954-3733
- E-mail: Hans.Schleibinger@nrc-cnrc.gc.ca

- Sherryl A. Schultz, Ph.D., C.I.H., C.S.P.
- Industrial Hygienist
- Searchlight Safety LLC
- 1349 Gordon Lane
- McLean, VA 22102
- Phone: 703-472-5384
- E-mail: sschultz8@cox.net

- Charles E. Seaman, B.S.N., M.P.H., R.I.A.Q.M.
- Environmental Education Foundation
- Charles E. Seaman Home Inspection Service
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Cheryl Ann Seaman, B.S.N., M.P.H., R.I.A.Q.M.
- Environmental Education Foundation
- Charles E. Seaman Home Inspection Service
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Joel Segal
- Office of Congressman John Conyers, Jr.
- 2426 Rayburn Building
- Washington, DC 20515
- Phone: 202-225-5126

- Katherine J. Seikel, M.B.A.
- Communications Coordinator
- U.S. Environmental Protection Agency
- Office of Pesticide Programs
- 1200 Pennsylvania Avenue, NW
- Washington, DC 20460
- Phone: 703-308-8272
- Fax: 703-305-5558
- E-mail: seikel.kathy@epa.gov

- Alayne Senior
- Risk Coordinator
- Vermont Department of Health
- Division of Health Protection
- 108 Cherry Street
- P.O. Box 70
- Burlington, VT 05402
- Phone: 802-865-7737
- Fax: 802-865-7745
- E-mail: asenior@vdh.state.vt.us

- Jennifer Y. Sheen
- Project Assistant
- Association of Clinicians for the Under-served
- Pediatric Asthma
- 1420 Spring Hill Road, Suite 600
- Tysons Corner, VA 22102
- Phone: 703-448-8528
- Fax: 703-749-5348
- E-mail: jsheen@clinicians.org

- William A. Shortencarrier
- Industrial Hygienist
- Letterkenny Army Depot
- Department of the Army
- Letterkenny Army Depot #90, (MCXR-LK-IH)
- Chambersburg, PA 17201
- Phone: 717-267-8822
- E-mail: william.a.shortencarrier@us.army.mil

- Karla K. Simon, M.S.P.H.
- Industrial Hygienist
- Center for Health Promotion and Preventive Medicine
- Department of the Army
- 5158 Black Hawk Road
- Building 5170, IHFS
- Aberdeen Proving Ground, MD 21010
- Phone: 410-436-5463
- E-mail: karla.simon@amedd.army.mil

- Daniel J. Smigal
- Industrial Hygienist
- National Institutes of Health
- Office of Research Services
- Division of Occupational Health and Safety
- 13 South Drive, Building 13, Room 3K04
- Bethesda, MD 20892
- Phone: 301-496-3353
- Fax: 301-402-0313
- E-mail: smigald@mail.nih.gov

- Alisa M. Smith, Ph.D.
- U.S. Environmental Protection Agency
- Indoor Environments Division
- 1200 Pennsylvania Avenue, NW, 6609J
- Washington, DC 20460
- Phone: 202-343-9372
- E-mail: smith.alisa@epa.gov

- Jack Spengler, Sc.D.
- Professor of Environmental Health & Human Habitat
- Harvard University
- Department of Environmental Health
- Landmark Center
- 4th Floor West, Room 406A
- 401 Park Drive
- Boston, MA 02215
- Phone: 617-384-8810
- Fax: 617-384-8819
- E-mail: spengler@hsph.harvard.edu

- Lynda L. Stanley
- Director
- National Research Council
- Federal Facilities Council
- 500 Fifth Street, NW, Room 944
- Washington, DC 20001
- Phone: 202-334-3374
- Fax: 202-334-3370
- E-mail: lstanley@nas.edu

- John G. Staudt, P.E.
- Environmental Engineer
- U.S. Department of Veterans Affairs
- Veterans Health Administration
- 810 Vermont Avenue
- Washington, DC 20420
- Phone: 202-273-5863
- Fax: 202-273-7071
- E-mail: jack.staudt@hq.med.va.gov

- Laurie R. Stillman, M.M.H.S.
- Executive Director
- Asthma Regional Council of New England
- The Medical Foundation
- 622 Washington Street, 2nd floor
- Dorchester, MA 02124
- Phone: 617 451-0049x 504
- Fax: 617-282-3950
- E-mail: lstillman@tmfnet.org

- William S. Stokes, D.V.M., D.A.C.L.A.M.
- Director, NTP Interagency Center for the Evaluation of Alternative Toxicological Methods (NICEATM)
- National Institutes of Health
- National Institute of Environmental Health Sciences
- Environmental Toxicology Program
- P.O. Box 12233, EC-17
- Research Triangle Park, NC 27709
- Phone: 919-541-7997
- Fax: 919-541-0947
- E-mail: stokes@niehs.nih.gov

- Eileen Storey, M.D., M.P.H.
- University of Connecticut Health Center
- 263 Farmington Avenue
- Farmington, CT 06030-6210
- Phone: 617-384-8823
- E-mail: storey@nso.uchc.edu

- LT Mark T. Strauss, M.P.H., R.E.H.S.
- Institutional Environmental Health Research
- Indian Health Service
- Department of Environmental Health Services
- 7227 Minter Place
- Takoma Park, MD 20912
- Phone: 301-402-9364
- E-mail: ms873u@nih.gov

- Greg Tate
- Occupational Safety and Health Specialist
- National Institutes of Health
- Office of Research Services
- Division of Occupational Health and Safety
- 13 South Drive, Building 13, Room 3k04
- Bethesda, MD 20892
- Phone: 301-402-8046
- E-mail: tateg@mail.nih.gov

- Joseph A. Terra, C.I.H.
- Senior Program Manager
- Federal Occupational Health
- 4550 Montgomery Avenue, Suite 950
- Bethesda, MD 20814
- Phone: 301-594-4883
- Fax: 301-594-4991
- E-mail: jterra@psc.gov

- Kenneth D. Thayer
- Building Operations Specialist
- U.S. Geological Survey
- Facilities Maintenance Branch
- 12201 Sunrise Valley Drive
- Reston, VA 20192
- Phone: 703-648-7517
- Fax: 703-648-7527
- E-mail: kthayer@usgs.gov

- Linda T. Thomas-Houston
- Regional Asthma Coordinator
- U.S. Environmental Protection Agency - Region 4
- Indoor Environment
- 61 Forsyth Street
- Atlanta, GA 30303
- Phone: 404-562-9152
- Fax: 404-562-9059
- E-mail: thomas.linda@epa.gov

- COL Ronald Torgerson, U.S.A.F. (Ret.), P.E., C.H.S.-III
- VP, Federal Solutions
- Versar, Inc
- 11990 Grant St., Ste. 500
- Northglenn, CO 80233
- Phone: 303-452-5700
- E-mail: torgeron@versar.com

- Alberto Treves, R.E.F.P.
- Assistant Director, International Cooperation Program
- Council of Educational Facility Planners International
- 4977 Battery Lane # 808
- Bethesda, MD 20814
- Phone: 301-654-3976
- Fax: 202-478-2183
- E-mail: treves@ed-space.com

- Susan M. Trinter
- Director
- Trinternational
- 2020 Pennsylvania Avenue, NW, #375
- Washington, DC 20006
- Phone: 202-296-1034
- E-mail: strinter@trinternatl.com

- Feng C. Tsai, Ph.D., M.S.
- Research Scientist
- California Department of Health Services
- Indoor Air Quality Program
- 850 Marina Bay Parkway, MS G365
- Richmond, CA 94804
- Phone: 510-620-2861
- Fax: 510-620-2825
- E-mail: ftsai@dhs.ca.gov

- Alyce L. Tucker
- Research Assistant
- Emory University
- Behavioral Sciences and Health Education
- 1525 Clifton Road
- Atlanta, GA 30322
- Phone: 267-971-5128
- E-mail: atucke2@sph.emory.edu

- Margaret R. Umfress
- U.S. Air Force Institute for Operational Health
- Health and Safety Division
- RSHI
- 2513 Kennedy Circle
- Brooks City-Base, TX 78235-5116
- Phone: 210-536-3386
- E-mail: margaret.umfress@brooks.af.mil

- Ravi Valluripalli
- American College of Preventive Medicine
- 1307 New York Avenue, NW, Suite 200
- Washington, DC 20005
- Phone: 202-207-0701
- E-mail: rv@acpm.org

- Emilia W. Vandenbroek
- Miles & Stockbridge
- Litigation Department
- 10 Light Street
- Baltimore, MD 21202
- Phone: 410-385-3467
- Fax: 410-385-3700
- E-mail: evandenbroek@milesstockbridge.com

- Ronald Varsaci, M.P.H.
- Environmental Health Officer
- U.S. Food and Drug Administration
- Center for Devices and Radiologic Health
- 9200 Corporate Boulevard, HFZ-020
- Rockville, MD 20850
- Phone: 301-827-0346
- Fax: 301-827-4947
- E-mail: ronald.varsaci1@fda.hhs.gov

- Jed Waldman, Ph.D.
- Chief, California Indoor Air Quality Program
- California Department of Health Services
- Environmental Health Laboratory
- 850 Marina Bay Parkway, (EHL)
- Richmond, CA 94804
- Phone: 510-620-2864
- Fax: 916-440-5855
- E-mail: jwaldman@dhs.ca.gov

- Kenneth M. Wallingford, C.I.H.
- IEQ Research Coordinator
- Centers for Disease Control and Prevention
- National Institute for Occupational Safety and Health
- 4676 Columbia Parkway, (R-11)
- Cincinnati, OH 45226
- Phone: 513-841-4327
- Fax: 513-458-7147
- E-mail: KWallingford@cdc.gov

- Greg Weatherman
- aerobioLogical Solutions Inc.
- 1300 Army Navy Drive, #1020
- Arlington, VA 22202-2020
- Phone: 703-920-6653
- Fax: 703-229-1234
- E-mail: gw@aerobiological.com

- Richard P. Weiblinger, M.P.H.
- Food and Drug Administration
- 9200 Corporate Boulevard
- Rockville, MD 20850
- Phone: 310-594-1307 x160
- E-mail: richard.weiblinger@fda.hhs.gov

- Steve A. Weil
- Board Chairman
- Coalition for Environmentally Safe Communities
- P.O. Box 535
- Olney, MD 20830
- Phone: 301-924-5490
- Fax: 301-924-0265
- E-mail: weilcm2@comcast.net

- Martin Weiland, P.E.
- Manager of Government Outreach
- American Society of Heating, Refrigerating and Air-Conditioning Engineers
- Washington Office
- 1830 L Street, NW, Suite 906
- Washington, DC 20036
- Phone: 202-833-1830
- Fax: 202-833-0118
- E-mail: mweiland@ashrae.org

- Charles J. Weiler, B.Arch.
- Architect
- 120 Warwick Road
- Haddonfield, NJ 08033-3707
- Phone: 856-428-0605
- Fax: 856-428-0605
- E-mail: cthew@aol.com

- Steven Welty, C.I.E., C.A.F.S.
- President
- Germ Safe Air
- 1251 Weatherstone Court
- Reston, VA 20194
- Phone: 703-927-7532
- Fax: 703-904-8112
- E-mail: GermSafeAir@aol.com

- Eric D. Werling, M.S.
- Environmental Engineer
- U.S. Environmental Protection Agency
- Office of Air and Radiation
- Indoor Environments Division
- 1200 Pennsylvania Avenue, NW
- Mail code: 6609J
- Washington, DC 20460
- Phone: 202-343-9495
- Fax: 202-343-2394
- E-mail: werling.eric@epa.gov

- Charles J. Weschler, Ph.D.
- Professor
- UMDNJ-Robert Wood Johnson Medical School
- Environmental and Community Medicine
- 161 Richdale Road
- Colts Neck, NJ 07722
- Phone: 732-530-0961
- Fax: 732-530-1453
- E-mail: weschlch@umdnj.edu

- Lois Wessel, C.F.N.P.
- Asthma Program Manager
- Association of Clinicians for the Under-served
- 7005 Westmoreland Avenue
- Takoma Park, MD
- Phone: 301-213-6733
- E-mail: lwessel@igc.org

- Sherri P. White, M.P.A.
- Program Analyst
- U.S. Environmental Protection Agency
- Office of Radiation and Indoor Air
- 1200 Pennsylvania Avenue, NW, MS 6609J
- Washington, DC 20460
- Phone: 202-343-9655
- Fax: 202-343-2393
- E-mail: white.sherri@epa.gov

- Thomas G. Wilcox, M.D., M.S.
- Senior Scientist
- SOMA Group, Inc.
- 839 Quince Orchard Boulevard, Suite E
- Gaithersburg, MD 20878
- Phone: 301-519-6880
- E-mail: Twilcox@somaonline.com

- Vernon Wilkes, C.I.H.
- Industrial Hygienist
- U.S. Department of Veterans Affairs
- Veterans Health Administration
- 810 Vermont Avenue, VHA - 10NB
- Washington, DC 20420
- Phone: 202-273-5870
- E-mail: wilkesv@va.gov

- RADM Robert C. Williams, P.E., BCEE
- Chief Engineer, USPHS
- Office of the Surgeon General
- U.S. Public Health Service
- 5600 Fishers Lane
- Parklawn Building, Room 18–55
- Rockville, MD 20857
- Phone: 301-443-4000
- E-mail: rwilliams@osophs.dhhs.gov

- Samuel H. Wilson, M.D.
- Deputy Director
- National Institutes of Health
- National Institute of Environmental Health Sciences
- 111 T.W. Alexander Drive, P.O. Box 12233
- Research Triangle Park, NC 27709-2233
- Phone: 919-541-3267
- Fax: 919-541-3592
- E-mail: wilson5@niehs.nih.gov

- James Woods, Ph.D., P.E.
- Executive Director
- The Building Diagnostics Research Institute, Inc.
- 5630 Wisconsin Avenue
- Suite 706
- Chevy Chase, MD 20815-4455
- E-mail: jewoods3@aol.com

- Robert Woodward, R.I.A.Q.M.
- Environmental Education Foundation
- AMT Mold Testing & Consulting
- 724 E. Iris Drive
- Gilbert, AZ 85296
- Phone: 480-659-9356
- E-mail: info@enviro-ed.org

- Sky Woodward
- Attorney
- Miles & Stockbridge P.C.
- Litigation Department
- 10 Light Street
- Baltimore, MD 21202
- Phone: 410-385-3606
- E-mail: swoodward@milesstockbridge.com

- Felicia Wu, Ph.D.
- Assistant Professor
- University of Pittsburgh
- Graduate School of Public Health
- 1337 Shady Avenue
- Pittsburgh, PA 15217
- Phone: 412-422-0263
- E-mail: fwu@eoh.pitt.edu