# Appendices

Appendix A Speaker Biographies

Appendix B Participant List

Appendix C Acknowledgments