# List of Acronyms

Acronyms
ETS: environmental tobacco smoke
HVAC: heating, ventilation, and air conditioning
IAP: indoor air pollution
IAQ: indoor air quality
MCS: multiple chemical sensitivity
RADS: reactive airways dysfunction syndrome
VE: Value Engineering

Organizations
AAAAI: American Academy of Allergy Asthma and Immunology
AAEE: American Academy of Environmental Engineers
AARST: American Association of Radon Scientists and Technologists
AFE: Association of Facility Engineers
AIA: American Institute of Architects
AIACOTE: American Institute of Architects Committee on the Environment
ALA: American Lung Association
APHA: American Public Health Association
APRHB: Air Pollution and Respiratory Health Branch
ARTI: Advanced Research and Technology Institute
ASCE: American Society of Civil Engineers
ASHRAE: American Society of Heating, Refrigerating and Air-Conditioning Engineers
ASTM: American Society for Testing and Materials
ATS: American Thoracic Society
ATSDR: Agency for Toxic Substances and Disease Registry
BASE: Building Assessment Survey and Evaluation Study
BEIR IV: Committee on the Biological Effects of Ionizing Radiation
BIDS™: Building Investment Decisions Support
BOMA: Building Owners and Managers Association
Cal/OSHA: California Division of Occupational Safety and Health
CDC: Centers for Disease Control and Prevention
CIAQ: Committee on Indoor Air Quality
CMU: Carnegie Mellon University
CPSC: Consumer Products Safety Commission
DARPA: Defense Advanced Research Projects Agency
DHHS: Department of Health and Human Services
DOC: Department of Commerce
DoE: Department of Education
DOE: Department of Energy
DRDS: Division of Respiratory Disease Studies
EPA: U.S. Environmental Protection Agency
EPAC: Engineer Professional Advisory Committee
FEMA: Federal Emergency Management Agency
FEMAC: Federal Energy Management Advisory Council
FFC: Federal Facilities Council
GAO: General Accountability Office
GSA: General Services Administration
HHE: Health Hazard Evaluation
HIE: Healthy Indoor Environment
HUD: Department of Housing and Urban Development
IBI: Integrated Business Institute
IDCE: International Design Center for the Environment
IIDA: International Interior Design Association’s
IOM: Institute of Medicine
ISEA: International Society of Exposure Assessment
ISIAQ: International Society of Indoor Air Quality and Climate
ISWG: Interagency Sustainability Working Group
JCAHO: Joint Commission on Accreditation of Healthcare Organizations
LEED: Leadership in Energy and Environmental Design
NAEPP: National Asthma Education and Prevention Program
NAHB: National Association of Home Builders
NAS: National Academy of Sciences
NCEH: National Center for Environmental Health
NCHS: National Center for Health Statistics
NCICAS: National Cooperative Inner City Asthma Study
NFPA: National Fire Protection Association
NHANES: National Health and Nutrition Examination Survey
NHLBI: National Heart, Lung, and Blood Institute
NIAID: National Institute of Allergy and Infectious Diseases
NIBS: National Institute of Building Sciences
NIEHS: National Institute of Environmental Health Sciences
NIH: National Institutes of Health
NIOSH: National Institute for Occupational Safety and Health
NIST: National Institute of Standards and Technology
NORA: National Occupational Research Agenda
NRC: National Research Council
NSF: National Science Foundation
NSLAH: National Survey of Lead and Allergens in Housing
ORIA: Office of Radiation and Indoor Air
ORISE: Oak Ridge Institute for Science and Education
OSG: Office of the Surgeon General
OSHA: Occupational Safety and Health Administration
OSTP: Office of Science Technology and Policy
OSW: Office of Solid Waste
PBS: Public Buildings Service
PHS: Public Health Service
PNIER: Program Needs for Indoor Environment Research
SAME: Society of American Military Engineers
SSPC: Standing Standard Project Committee
TISP: The Infrastructure Security Partnership
TSAC: Technical and Scientific Advisory Committee
USDA: U.S. Department of Agriculture
USGBC: U.S. Green Building Council
WHO: World Health Organization