# Taxonomy Help

## Overview

The National Center for Biotechnology Information (NCBI) Taxonomy includes organism names and classifications for every sequence in the nucleotide and protein sequence databases of the International Nucleotide Sequence Database Collaboration (INSDC). It provides a framework for clustering elements within other domains of NCBI web pages, for internal linking between domains of the Entrez system and for linking out to taxon-specific external resources on the web and relevant publications. It is also the standard nomenclature and classification repository for the International Nucleotide Sequence Database Collaboration (INSDC) that comprises of GenBank, the European Molecular Biology Laboratory (EMBL) and DNA Data Bank of Japan (DDBJ). It consists of a curated set of names and classifications for all of the source organisms represented in the INSDC.

The NCBI taxonomy databases contain a list of current names as well as several synonyms and other variants. These are determined to be nomenclaturally correct or valid (as defined by the four main codes of nomenclature), classified in an approximately phylogenetic hierarchy (depending on the level of knowledge regarding phylogenetic relationships of a given group). This also includes a number of names that exist outside the jurisdiction of the four main codes. The focus is on nomenclature and systematics, rather than documenting the description of taxa. It requires a curator to select a current name out of all possible synonyms and other variants for a specific taxon. This is done by a specialist at NCBI Taxonomy, relying on published taxonomic data and external expert opinion. This single, current name are indicated on all INSDC records.

## A brief history

NCBI Taxonomy, included in the first version of Entrez in 1991, was the first system to link nucleotides and proteins from numerous disparate sources with different taxonomic classification systems. In 1996, the first version of the NCBI Taxonomy Web Browser was presented to the public and the International Nucleotide Sequence Database Collaboration (INSDC) decided to adopt NCBI Taxonomy as the only source for taxonomic classification in order to maintain consistency among databases. This included the decision that all issues regarding nomenclature and classification would be resolved prior to the public release of any sequence data. INSDC partners now send any requests for new names (taxonomy “consults”) to NCBI Taxonomy curators before final data release. Up until the beginning of 2026, the NCBI taxonomy pages only display taxa that are linked to public sequence entries. A new change means that 1) all newly added names are released immediately (it is not dependent on the release of associated sequence records), and 2) all taxa, regardless of their association with public sequence entries, are be available from the NCBI Taxonomy pages.

## Access

### NCBI Datasets

#### Web

To find NCBI Taxonomy data on the web, start from the NCBI Datasets Taxonomy landing page (https://www.ncbi.nlm.nih.gov/datasets/taxonomy/).

#### Command-line tools (CLI)

To find NCBI Taxonomy data using the NCBI Datasets command-line tools, start with the How-to guide for Taxonomy (https://dev.ncbi.nlm.nih.gov/datasets/docs/v2/how-tos/taxonomy/).

#### API

There are several API endpoints available for obtaining taxonomy data. In most cases, we recommend using the NCBI Datasets command-line tools instead of the API, because the command-line tools are more user-friendly and include features like query term validation, built-in retries and handling of complex queries that require multiple API calls in a single step.

### Taxonomy FTP Site

Taxonomy information is available from a set of taxonomy dump files that can be downloaded from the Taxonomy FTP (https://ftp.ncbi.nih.gov/pub/taxonomy/new_taxdump/) Site as a compressed archive, new_taxdump. For more information about the contents of these files, see the taxonomy dump README file (https://ftp.ncbi.nih.gov/pub/taxonomy/new_taxdump/taxdump_readme.txt).

## Codes of Nomenclature

NCBI Taxonomy distinguishes between formal and informal names. Formal names are declared based on rules laid down in four relevant codes of nomenclature (although other codes do exist). These are the International Code of Nomenclature for algae, fungi, and plants (ICNafp (https://www.iaptglobal.org/icn)), the International Code of Nomenclature of Prokaryotes (ICNP (https://the-icsp.org/code-of-nomenclatur)), and the International Code of Zoological Nomenclature (ICZN (https://www.iczn.org/the-code/the-code-online/)). The viruses are governed by the International Code of Virus Classification and Nomenclature (ICVCN (https://ictv.global/about/code), also referred to as the ICTV Code). Informal names follow internal rules that are dictated by practical considerations outside of these codes. For example, names lacking species epithets are commonly applied to GenBank records. Names published under a newly introduced code, the Code of Nomenclature of Prokaryotes Described from Sequence Data (SeqCode) will be treated similarly to effectively published names under the ICNP but labelled separately to distinguish them.

## Treatment of Type Material in NCBI Taxonomy

The word ‘type’ forms part of many compound terms used by taxonomists. In all the above-mentioned codes one or more types is designated as an objective standard to fix the scientific name of the species or infraspecies (i. e. subspecies, variety or forma). The type of a species or infraspecies (taxon) is designated when the new taxon is described and illustrates the trait(s) that distinguish the new taxon from all other comparable taxa. Viruses rely on lists of names approved by the International Committee on Taxonomy of Viruses (ICTV) and their usage of exemplars, focused on sequence accessions do not apply.

Under the ICNafp and ICNP, types are never living and usually consist of dried or pickled specimens or physiologically inactivated cultures. Prokaryotic types (Bacteria and Archaea) are always living cultures (type strains). The most common types encountered, as well as certain non-nomenclatural terms, are listed below. Types may be indicated by collector name and number plus institution code where the specimen is deposited, and/or institution accession or barcode number. We list the abbreviations of the nomenclatural codes that use them in parentheses (see above).

- Type material (not designated in any code). This is an internal term to NCBI Taxonomy, and if not further designated, refers to specimens or cultures where the type of type is unknown or unspecified.
- Holotype (ICNafp, ICNP). is the most important. There is only one holotype, usually a single specimen, and it is the ‘name-bearer’ of the described taxon. It serves as the standard to which all subsequent examples of the described taxon are compared. The equivalent term we use for prokaryotes is type strain (ICNP) and there can be multiple co-identical type strains, cultured from a single source.
- Neotype (ICNafp, ICNP, ICZN). If the holotype is lost or destroyed, a neotype specimen is designated from a collection considered to be representative of the original holotype. There is only one neotype. The equivalent term we use for prokaryotes is neotype strain (ICNP) with multiple neotype strains possible when cultured from a single source.
- Isotype (ICNafp). Under the ICNafp one or more duplicate specimens from the holotype collection can be deposited in other institutions. Usually the collection number is the same as the holotype, but the institution code has to be different. Iso- can be appended to other kinds of types to indicate duplicates, e.g., isosyntype, etc. Isotype is not a formally accepted term in the ICZN.

The next set of types are considered of lower nomenclatural importance, because they are derived from specimens that act to inform and expand the concept of the preceding set of types and will generally be different genetically, although still potentially closely related.

- Paratype (ICNafp, ICZN). One or more additional specimens chosen to further illustrate traits in the described taxon.
- Epitype (ICNafp): In botanical nomenclature only, a type designated to expand on the original holotype concept. There should be only one epitype.
- Culture from type (ICNafp): Also, sometimes designated ex-type, e.g., ex-holotype, etc. There can be multiple of these. The types of cultivable, microbial eukaryotes must be inactivated and one or preferably more living cultures are extracted from the type and maintained in culture collections. Since these are living, they do not have formal status as type, but since they will often be the source of DNA sequence data, they are annotated and indicated as type material.
- Reference material or reference strain (not designated in any code): The reference material and reference strain qualifiers are internal GenBank terms used to capture any reference strain or material exclusively of types. These terms can include specimens or cultures that don’t have nomenclatural standing but nevertheless could have name-bearing value. For example, Candidatus prokaryotic names, are names proposed for new species that have not been formally described by the ICNP will receive reference strain designations, since technically they do not possess types.

Additional types are listed under the controlled vocabulary for the INSDC: http://www.insdc.org/controlled-vocabulary-typematerial-qualifer

## Data Model

Each sequence record in the INSDC databases maps to a taxonomy record, or node, in the NCBI Taxonomy database at the level of species or below (an exception is made for patent entries). Each NCBI Taxonomy record, or taxonomic node, usually includes the following attributes: a primary, or current scientific name, one or more secondary names, such as synonyms or common names, and a public, stable, unique identifier, the NCBI Taxonomy identifier (TaxId). These attributes and additional optional attributes are described below.

### Taxonomic node attributes

#### TaxId

Each taxonomic node has a stable, unique numerical identifier, the taxonomy identifier (TaxId). If it was the result of merging other taxonomic nodes it will also contain secondary TaxIds for those nodes. The primary TaxId is the one that will be displayed but searching on secondary TaxIds will provide the same result.

#### Current scientific (primary) name

Each taxonomic node has a current scientific name (primary) name (a formal or informal name).

In publications this can be standardized as a current scientific name with its TaxId displayed as “ncbitaxon” followed by a number, e.g.,

Homo sapiens ncbitaxon:9606

#### Relational terms

Relational terms indicate relationships between secondary names and current scientific (primary) names. For instance, the first name attached to a species description is indicated as the basionym. The currently accepted name is indicated as the current scientific name (which could be the same as the basionym). These terms also differentiate between different synonyms: heterotypic synonym and homotypic synonym. Homotypic (or objective synonyms), are names based on the same type (see discussion of type material). Heterotypic (or subjective) synonyms are based on different types that were considered distinct taxa when they were first proposed, but subsequently considered to belong to the same taxon, documented in a publication or other authoritative source. Group names (previously called blast names) behave differently than the other assigned name categories. If a group name is assigned to a taxonomic node it is inherited by all the child nodes until it encounters another designated group name.

#### Properties

The “specified” property is currently defined as: formal names (binomials, trinomials or infraspecies names) applied at ranks of species and below. This property also includes names with conventions for formal use, but outside of rules officiated by a code, e.g., forma specialis and candidatus names. This also includes replaced virus species synonyms that were moved below species.

Code “compliant”, or formal names, are those names which are strictly recognized as valid under their relevant code at any rank. At species and below they should always be potentially associated with type material, except for a subset of hybrid names that consist of other species names.

Information about whether a name is code compliant, or formal, is available in the taxonomy data report (https://dev.ncbi.nlm.nih.gov/datasets/docs/v2/reference-docs/data-packages/taxonomy/#taxonomy-report) and taxonomy summary (https://dev.ncbi.nlm.nih.gov/datasets/docs/v2/reference-docs/data-packages/taxonomy/#taxonomy-summary) files. In the taxonomy data report, the field name, currentScientificNameIsFormal, is used, while in the taxonomy summary file, the column name is Scientific name is formal.

Information about both “specified” and “compliant” properties are available in the nodes.dmp file included as part of the compressed archive, new_taxdump, available from the NCBI Taxonomy FTP site (https://ftp.ncbi.nlm.nih.gov/pub/taxonomy/new_taxdump).

#### Ranks

The highest levels in NCBI Taxonomy are cellular root (for cellular organisms) and acellular root (for viruses). Cellular organisms are further classified as being in one of three domains: Archaea, Bacteria, or Eukaryota. Viruses are usually classified as being in one of seven recognized realms. Where possible, the following seven standard ranks are universally applied throughout the classification: kingdom, phylum, class, order, family, genus, and species. Many other ranks, including several below species, are in use. Some of these ranks are not defined formally by any code. Clades are ranks that can appear anywhere in the lineage without breaking the order. Several nodes, notably virus names below species, are displayed as “no rank”.

#### Name status

A range of properties inherent to a name can be assigned a name status based on its treatment by a specific code. Where names do not meet the requirements of their respective codes of nomenclature they will be displayed with the name status in parentheses, with a note attached and placed in an unclassified bin. Some examples are listed below (but more exist in NCBI Taxonomy):

Name status | Note displayed
effective name | This taxonomic name has been effectively published but not validly published under the rules of the International Code of Nomenclature of Prokaryotes (Bacteriological Code).
candidatus name | A provisional name for well-characterized but as-yet uncultured organisms.
orth. var. | ‘Orth. var.’ (= orthographic variant) refers to a name not following standard rules of orthography, such as gender disagreement between genus and species, either when originally published or mistakenly corrected in later publications; includes names which are “incorrect original spellings” and “incorrect subsequent spellings” in zoological parlance.
ICTV accepted | Name is currently accepted by the International Committee on Taxonomy of Viruses.
nom. inval. | ‘Nom. inval.’ (= nomen invalidum, = invalid name) refers to a name not published in accordance with rules enumerated in the International Code for algae, fungi and plants.
nom. illeg. | ‘Nom. illeg.’ (= nomen illegitimum, = illegitimate name) refers to a validly published name that is not in accordance with the particular rules of its relevant Code of Nomenclature.
nominotypical infraspecies | This nominotypical infraspecies name or autonym shares type material with its parent species.
SeqCode name | Name as published under the Code of Nomenclature of Prokaryotes Described from Sequence Data (SeqCode) This taxonomic name is published under the Code of Nomenclature of Prokaryotes Described from Sequence Data (SeqCode) and is not considered validly published nor have standing in nomenclature under the rules of the International Code of Nomenclature of Prokaryotes (ICNP).
abolished name | Name is currently abolished by the International Committee on Taxonomy of Viruses.

#### Genetic codes

NCBI maintains a summary of genetic codes across the tree of life here: The Genetic Codes (https://www.ncbi.nlm.nih.gov/Taxonomy/Utils/wprintgc.cgi)

Changes to a genetic code are highly impactful and new codes are only introduced where clear experimental evidence is available.

#### Metagenome/Environmental nomenclature

In addition to the classification based on taxonomic nomenclature, NCBI Taxonomy contains entries that are placed under unclassified sequences (https://www.ncbi.nlm.nih.gov/datasets/taxonomy/12908/). These include names for metagenomes labelled according to where they were sampled and is divided into two main categories, ecological metagenomes (https://www.ncbi.nlm.nih.gov/datasets/taxonomy/410657/) and organismal metagenomes (https://www.ncbi.nlm.nih.gov/datasets/taxonomy/410656/). SeqCode (discussed under codes of nomenclature) also covers many environmentally sampled sequences.

#### Images

In addition to names, images are also curated in NCBI Taxonomy. These should not be used for diagnostic purposes and are curated from images released under public domain or via a Creative Commons license. Image information is available in the images.dmp file included as part of the compressed archive, new_taxdump, available from the NCBI Taxonomy FTP site (https://ftp.ncbi.nlm.nih.gov/pub/taxonomy/new_taxdump).

Further reading

## Additional information

This document is a copy of the NCBI Datasets Taxonomy overview (https://dev.ncbi.nlm.nih.gov/datasets/docs/v2/data-processing/taxonomy-processing/taxonomy/).

There is also a description of recent updates in NCBI Taxonomy (https://dev.ncbi.nlm.nih.gov/datasets/docs/v2/data-processing/taxonomy-processing/taxonomy-updates/).