# Searching for Data by Submitter or Author

Can I search SRA by a submitter or author’s name?

Unfortunately, SRA is not indexed by the author/submitter name, so you cannot use this as a search term. Instead, search PubMed (http://www.ncbi.nlm.nih.gov/pubmed/) using the author/submitter’s name. If there is a publication by the suthor/submitter that is associated with SRA data, when you find the publication in PubMed, you will also find a link to the SRA data within the PubMed publication record.

Unfortunately, SRA and Pubmed are not reciprocally indexed, so you cannot search SRA with the author/submitter’s name to get a link for a PubMed article.