# Searching for PubMed Articles Associated with SRA Data

How do I find PubMed articles that have mouse SRA data associated with them?

To find PubMed articles that have mouse SRA data associated with them, do the following:

1 Go to the Entrez SRA (http://www.ncbi.nlm.nih.gov/sra) page.
2 Enter mus musculus[organism] AND "sra pubmed"[filter] in the search box at the top of the page.
3 Click the “Search” button.
4 Your search results will be presented as a list of mouse experiments (SRX/ERX/DRX accessions) in the SRA that have been reported in a PubMed article.