# Searching for Data

This section of the Sequence Read Archive (SRA) Knowledge Base contains:

- Instructions for searching for specific data types
- Suggestions for search terms
- Instructions for using SRA search tools
- Answers to common problems that happen while searching
- Information on how to interpret your search results.

To begin searching this section of the Sequence Read Archive Knowledge Base, you can either:

- Enter your search word(s) text in the text box at the top of the page and click on the “Go” button, OR
- Click on any of the “SRA Knowledge Base” sub-categories listed in the “Contents” section below to go to the sub-category of your choice.