# Human Variation Batch Submission Quick Start

This Quick Start guide is intended for the users of the web-based Human Variation: Annotate and Submit Batch Data (http://www.ncbi.nlm.nih.gov/projects/SNP/tranSNP/VarBatchSub.cgi) site, and contains information and step by step instructions for an array of topics covering the entire variation batch submission process. The subject matter in this guide ranges from creating a handle and filling out the submission form, to the steps of submission processing and what to do should your validation fail.

As the Variation Batch Submission Quick Start guide is arranged as a topical reference, you don’t have to read it from beginning to end to find specific pieces of information. If there are topics you’d like to see in this guide that are not currently included, please email snp-admin.

Please consult the dbSNP FAQ Archive submission section, which contains answers to many complex submission questions. If you still are unable to find the answer to your question, email SNP submissions.

To begin searching this section of the dbSNP FAQ Archive, you can:

Enter your search word(s) text in the text box at the top of the page and click on the “Go” button

OR

Click on any of the “Human Variation Batch Submission Quick Start” sub-categories listed in the “Contents” section below to navigate to the sub-category of your choice. Once you are in the sub-category, you will be presented with a grey box containing the questions for the sub-category you selected. Clicking on a question in this list will allow you to navigate to the answer.