# Submitting Data

I’ve filled out the Excel batch submission worksheet. How do I submit it?

Fill out the “New Submission (http://flexo.be-md.ncbi.nlm.nih.gov/projects/SNP/tranSNP/VarBatchSub.cgi?rm=submit)” form which you can access by clicking on the blue “GO!” link located to the right of the “New Submission” section head near the top of the Variation Batch Submission page. Fill out all the requested fields, attach your submission worksheet, and click the “Upload!” button. (04/10/08)