# How do I Update Data I’ve already Submitted?

I’ve loaded data to dbSNP, but see now that I need to change some of it. Can I do that?

1 You can update data from a variation batch submission by doing the following:
2 Login to the Human Variation Batch Submission (http://www.ncbi.nlm.nih.gov/projects/SNP/tranSNP/VarBatchSub.cgi) website.
3 Locate the submission you want to update in the “Completed Submissions” section and click on the submission to open it.
4 Click the “update” button and follow the instructions.

Please note: the new data used to update a selected submission will entirely replace any previously submitted data for that submission. (04/13/08)