# Searching for a Class of Variations in dbSNP

## Searching for indels in dbSNP

If I want to download all the indels from dbSNP, do I download the SNP table? If so, where is it?

Before I give you the steps to download the SNP table, I would like to mention that you can also get all the indels housed in dbSNP using an Entrez Search:

1 Go to the Entrez SNP page (http://www.ncbi.nlm.nih.gov/sites/entrez?db=snp), click on the grey “Limits” tab near the top of the page.
2 Once you are on the limits page (http://www.ncbi.nlm.nih.gov/sites/entrez), go to the “SNP Class” box, and click on “in del”.

Here are the steps for downloading the SNP table:

1 Go to the left blue side bar on the dbSNP home page (http://www.ncbi.nlm.nih.gov/SNP), and Click on “General”.
2 From the released set of choices, click on “FTP Download”.
3 For the purpose of this example, I will assume you need the SNP table for human. To find it, you would go to the human /database/organism_data/ directory.

(10/08/08)