# Searching for SNPs in Raw Sequence Data

Can NCBI provide me with a tool that will aid me in identifying SNPs from raw sequence data?

NCBI doesn't have a tool for identifying SNPs, but the Sanger institute offers a polymorphism detection tool called “ssahaSNP (http://www.sanger.ac.uk/Software/analysis/ssahaSNP/)” for academic use, and you can always try searching PubMed for publication information (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?CMD=search&DB=pubmed&term=snp%20detection%20software) on SNP detection software. (1/30/06)