# Searching for SNPs in a NCBI Genome Build and in BAC Clones

## Searching for SNPs contained in the NCBI Genome Build

How can I get the SNP data for NCBI’s genome build 34?

To get the mapping coordinates for build 34.3, please see the SNPContigLoc_34_3.bcp.gz table for the species of interest on the dbSNP FTP site.

You might also wish to consult tables b125_SNPMapInfo_34_5 and b125_ContigInfo_34_5. in the same FTP directory. Please see the Data Dictonary (http://www.ncbi.nlm.nih.gov/SNP/snp_db_list_table.cgi) for table descriptions of the above tables.

Please note that some refSNP (rs) numbers might have been merged ( if they are found to map the same location at a later build). The rs merge history is located in the RsMergeArch table, located in the same FTP directory as the aforementioned tables. (4/28/06)

## Searching for SNPs in BAC Clones

Why does the "[ACC]" term used in SNP searches return the following error message: “The following term was not found: AC019340[ACC]”.

We only index sequence accession numbers (NT and NM) that have SNPs mapped directly to them, and do not project them onto BAC clone sequences (ie. AC000120). (3/6/07)