# Locating SNPs in a Protein Family

How do I search for a particular protein family that contains SNPs?

You can search for proteins that have SNPs from the NCBI protein database (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=protein) using the protein_snp subset.

Example:

1 Search Entrez Protein using the protein accession and protein_snp subset (sb) as search terms.
2 Then search Entrez Protein using the protein found in the previous step and protein_snp[sb] as search terms (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?CMD=search&DB=protein&term=lipoprotein%20lipase%20AND%20protein_snp%5bsb%5d).
3 Select Links located on the far right side of the page for the protein of interest, and when the drop-down menu appears, select SNP. This will take you to a SNP page that contains a list of the SNPs for the protein entry.
4 Locate the display box at the bottom left-hand corner of the page and choose one of the SNP reports (FASTA, ASN.1, Flat File, or XML), which will easily allow you to parse the data.