# Searching dbSNP for Variations and Variation Data

This section contains FAQs that provide information about general dbSNP search options as well as FAQs that cover specific SNP searches — everything from searching for SNPs in populations to searching for SNPs in genes and chromosomes. There are FAQs in this section about searching for SNP primers, and FAQs about searching for a SNP with a specific ID. There are FAQs that show you how to search for specific SNP data, how to conduct Batch queries under various circumstances, and FAQs that show you how to locate SNPs using sequence homology (BLAST). There are even FAQs that show you how to find dbSNP statistical data and data histories or historic data.

To begin searching this section of the dbSNP FAQ Archive, you can:

Enter your search word(s) text in the text box at the top of the page and click on the “Go” button

OR

Click on any of the “Searching dbSNP” sub-categories listed in the “Contents” section below to navigate to the sub-category of your choice. Once you are in the sub-category, you will be presented with a grey box containing the questions for the sub-category you selected. Clicking on a question in this list will allow you to navigate to the answer.