# Downloading Specific Schema Tables

Rather than downloading the entire database, how do I download specific tables from the dbSNP schema?

Use the bcp table images and the table schema are located in the dbSNP FTP shared schema directory. The naming convention of the files is the same as that in the ER diagram.