# Submitting SNPs using a Reference Sequence Position

I have to submit SNPs discovered by my group, but do not have any of the sequence data for the variations — just the position on a reference sequence.

There are three ways you can submit:

1 If you do not have the sequence data, but have a GenBank accession and a position as reference, you can send this information to dbSNP submissions, and we can use this information to get the sequence from GenBank.
2 You can now submit batches of SNPs yourself using dbSNP’s Human Variation: Annotate and Submit Batch Data (http://www.ncbi.nlm.nih.gov/projects/SNP/tranSNP/VarBatchSub.cgi) site, although you must be able to describe the variations using HGVS nomenclature (http://www.hgvs.org/mutnomen/) in order to submit them. Click on the “submission help” link located at the upper right corner of the page for help getting started.
3 Finally, if you want to submit you variations one at a time, you can use the Human Variation: Search, Annotate, Submit (http://www.ncbi.nlm.nih.gov/SNP/tranSNP/tranSNP.cgi) site. Here is an example of how this resource might be used for a submission: if you query using NM_000212.2:c.176T>C as your search term, you will find that rs5918 (http://www.ncbi.nlm.nih.gov/SNP/snp_ref.cgi?rs=5918) has already been assigned to that location. You can then add value that SNP by providing the URL to your database. (04/30/08)