# External Submission Tools

Can you tell me anything about SNaPshot, or can you point me toward a literature source for it?

There are some submitter methods that use SNaPshot in dbSNP: See this URL (http://www.ncbi.nlm.nih.gov/SNP/snp_tableList.cgi?fld=Method+description&cond=contains&str=snapshot&snapshot=cond&str=snapshot&type=method&starts+with=&fld=Method+description&fld=str&go=Search+%28case+insensitive%29&.cgifields=cond&.cgifields=fld), but we don't have details for this protocol.

You can try a Google search (http://www.google.com/search?hl=en&lr=&ie=ISO-8859-1&q=SNaPshot+SNP+assay&btnG=Google+Search) or try to contact Applied Biosystems (http://www.appliedbiosystems.com/catalog/myab/StoreCatalog/products/CatalogDrillDown.jsp?hierarchyID=101&category1st=111762&category2nd=19210), the manufacturer of SNaPshot.