# Field Definitions

What are the definitions of contig_chr, contig_pos, and contig_build_id?

contig_chr is the chromosome for this SNP (if known).contig_pos is the position on the chromosome.contig_build_id is the build in which the SNP was last edited.

What is the definition of "contig_pos=0"?

This is a case in which the SNP has not been mapped to the human genomereference sequence.