# Entrez SNP and Entrez Gene Response Pages

I was looking up the enzyme "catalase" on Entrez Gene and found the associated SNP page. It states that there are 240 entries for Homo Sapiens. Are there 240 SNP variations that have currently been identified?

There are 240 unique reference SNPs in dbSNP for the human CAT gene. There may be more identified in the literature that have yet to be submitted to dbSNP. (5/22/06)

Using Entrez SNP Search to look for a SNP, I got a graphical response page with the refSNP(rs) number. Where is the legend for this graphics?

You can find the legend by clicking on the word "Legend (http://www.ncbi.nlm.nih.gov/projects/SNP/EntrezSNPlegend.html)" for a full description of "Entrez Graphic Summary" display. (5/22/06)

Entrez Gene states that "catalase" has 240 entries for Homo sapiens. Does that mean 240 SNP variations have currently been identified?

There are 240 unique reference SNPs in dbSNP for the human CAT gene. There may be more identified in the literature that have yet to be submitted to dbSNP. (5/22/06)