# Displaying Reports

How do I get the genetic position of a SNP (i.e. centimorgan [cM]) displayed on top of the SNP’s physical position(bp)?

dbSNP contains only the SNP’s physical position.(9/18/07)