# Discrepancies between Cluster Report data and Other Genome Resources

Ensembl shows rs3210531 on chromosome 11 strand +1, however, NCBI shows it on chromosome 6 strand -1. Why?

We conduct two different mapping procedures for each SNP. First one places the SNP on contigs, and according to our database, rs3210531 hits chromosome 11 across all assemblies:

snp_id | pos | chr | assembly
3210531 | 46406925 | 11 | reference
3210531 | 46598418 | 11 | Celera
3210531 | 46157042 | 11 | HuRef

An additional hit to chr6 was rejected due to our "absolute hit" strategy. This strategy states that if the mapping process finds a 100% identity hit, then the process will reject hits with lower scores as irrelevant.

Mapping to underlying sequences is a separate process and it produced the following hits for rs3210531:

snp_id | offset | accession | accession_ver | aln_quality
3210531 | 366 | U14972 | 1 | 1
3210531 | 423 | BC001955 | 1 | 1
3210531 | 423 | BC005012 | 1 | 1
3210531 | 369 | BC001032 | 2 | 1
3210531 | 367 | BC070235 | 1 | 1
3210531 | 379 | BC071946 | 1 | 1
3210531 | 456 | BC073799 | 1 | 1
3210531 | 418 | NM_001014 | 3 | 1

We are working now on a synchronization mechanism for two these processes. (09/29/08)

The data for rs13306584 is not the same in the UCSC Genome Browser, Ensembl, or dbSNP. Why is this?

The UCSC Genome Browser and Ensembl haven't yet updated to build 128, which is the current dbSNP build. USCS is updated only to build 126, while Ensembl is updated to build 127. Since the data for rs13306584 has changed between these three builds, the data for the three databases will not be the same until the UCSC Genome Browser and Ensembl update to dbSNP build 128. (11/23/07)