# Batch Reports

Why do we find rs386014 displayed in both HLA-A’s and HCG4P6’s batch report?

rs386014 is annotated to HLA-A on the Celera assembly using the gene model (contig---> mRNA---> gene). The same SNP is associated with HCG4P6 because the variation has been mapped within 2 kb of an mRNA transcript for the HLA complex group 4 pseudogene 6.

(1/3/06)