# dbSNP and Phenotype Records

Does dbSNP include curated phenotypic information?

dbSNP does not contain curated phenotypic information, but we hope to include some in the future. We do have some SNPs mapped to allelic variants in the Online Mendelian Inheritance in Man (OMIM (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?db=snp&cmd=search&term=snp_omim%5Bsb%5D)) database.

I would like to conduct a study where I correlate certain body features with SNP frequencies and would like to know if SNP donor records and facial pictures are available to the scientific community.

We do not have facial pictures or other phenotype information on the donors whose genotype data are submitted to us. Most of our individuals are from the NIH Polymorphism Discovery Panel and Coriell.We do have one population frequency submission (http://www.ncbi.nlm.nih.gov/SNP/snp_viewTable.cgi?type=pop&pop_id=505) that has a description of the craniofacial phenotype of the populations, but no individual genotype data were submitted within this population.