# STR Naming Convention

How are STRs named?

The D segment numbers commonly used for microsatellites are issued by the Genome Database (http://en.wikipedia.org/wiki/GDB_Human_Genome_Database) (GDB) (9/6/06)