# Personal SNP Screenings

Someone recently approached a colleague of mine and suggested she get a SNP screening to determine what nutrients she should be taking. She was also told that she would be able to get customized supplements based on the results of her screening. Is this true?

Please read the following disclaimer (http://www.ncbi.nlm.nih.gov/About/disclaimer.html#disclaimer) that applies to all NCBI resources:

“Medical Information

It is not the intention of NLM to provide specific medical advice, but rather to provide users with information to better understand their health and their diagnosed disorders. Specific medical advice will not be provided, and NLM urges you to consult with a qualified physician for diagnosis and for answers to your personal questions.”

You could try searching PubMed (http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?DB=pubmed), or Medline Plus (http://medlineplus.gov/), both of which may have relevant articles or information.(4/28/06)